# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of heptachlor and heptachlor epoxide is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of heptachlor and heptachlor epoxide is located in Table 4-2.

Table 4-1 Chemical Identity of Heptachlor and Heptachlor Epoxide^a^

Characteristic | Heptachlor | Heptachlor epoxide
Synonym(s) | 3-Chlorochlordene; 1,4,5,6,7,8,8a-hepta-chloro-3a,4,7,7a-tetrahydro-4,7-methanoindene; 1,4,5,6,7,8,8-heptachloro-3A,4,5,5a tetrahydro; alpha-dicylcopentadiene, 3,4,5,6,8,8a heptachloro, and others | Epoxyheptachlor; 1,4,5,6,7,8,8a-hepta-chloro-2,3-epoxy-3a,4,7,7a-tetra-hydro-4,7-methanoindene; 4,7-methanoindan, 1,4,5,6,7,8, 8-heptachloro-2,3-epoxy-3a,4,7,7a-tetrahydro-; 2,5-methano-2h-indeno (1,2-b)oxirene, 2,3,4,5,6,7,7-heptachloro-1a,1b,5,5a,6,6a-hexahydro-, (1aalpha,1bbeta,2alpha,5alpha,5abeta,6beta,6aalpha)-
Registered trade name(s) | Basaklor; Gold Crest H-60; Termide; Heptagran; Heptagranox; Heptamak; Heptamul; Soleptax; Velsicol 104 | Velsicol 53-CS-17
Chemical formula | C_10_H_5_Cl_7_ | C_10_H_5_Cl_7_O
Chemical structure
Identification numbers:
CAS registry | 76-44-8 | 1024-57-3
NIOSH RTECS | PC0700000
EPA hazardous waste | P059 | D031
OHM/TADS | 7216526 | 833300216
DOT/UN/NA/IMDG shipping | UN 2761, UN2782, UN 2995, UN2996, IMO 3.0, IMO 6.1 | UN 2761, UN2782, UN 2995, UN2996, IMO 3.0, IMO 6.1
HSDB | 554 | 6182
NCI | C00180

a All information obtained from HSDB 2007a for heptachlor or HSDB 2007b for heptachlor epoxide unless otherwise noted.

CAS = Chemical Abstracts Services; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Heptachlor and Heptachlor Epoxide^a^

Property | Heptachlor | Heptachlor epoxide
Molecular weight | 373.32 | 389.40
Color | White (pure); tan (technical grade)^b^ | White^b^
Physical state | Crystalline solid | Crystalline solid^b^
Melting point | 95–96 °C (pure); 46–74 °C (technical grade)^c^ | 160–161.5 °C
Boiling point | 145 °C | No data
Specific Gravity:
at 9 °C | 1.57 | No data
Odor | Camphor-like | No data
Odor threshold:
Water | No data | No data
Air | 0.3 mg/m^3^ | 0.3 mg/m^3^
Solubility:
Water at 25 °C | 0.05 mg/L^d^ | 0.275 mg/L^d^
Organic solvent(s) | Soluble in most organic solvents | Soluble in most organic solvents^b^
Partition coefficients:
Log K_ow_ | 6.10 | 5.40
Log K_oc_ | 4.34^e^ | 3.34–4.37^f^
Vapor pressure
| 3×10^−4^ mmHg^g^ at 20 °C | 1.95×10^−5^ mmHg at 30 °C ^h^
| 3×10^−4^ mmHg at 25 °C | No data
Henry’s law constant:
at 25 °C | 2.94×10^−4^ atm-m^3^/mol | 3.2×10^−5^ atm-m^3^/mol
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | Highly flammable | Non-combustible
Conversion factors | 1 ppm=15.27 mg/m^3^ at 25 °C, 1 atm | 1 ppm=15.93 mg/m^3^ at 25 °C, 1 atm
Explosive limits | Non-combustible | Containers may explode when heated

a All information obtained from HSDB 2007a for heptachlor or HSDB 2007b for heptachlor epoxide unless otherwise noted

b IARC 1974

c Worthing and Walker 1987

d EPA 1987

e Chapman 1989

f Estimated from Lyman et al. 1982

g ACGIH 1986

h Nash 1983