# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Heptachlor Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Heptachlor
CAS Numbers: | 76-44-8
Date: | August 2007
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 19
Species: | Rat

[underlined: Minimal Risk Level]: 0.0006 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Amita Rani BE, Krishnakumari MK. 1995. Prenatal toxicity of heptachlor in albino rats. Pharmacol Toxicol 76(2):112–114.7746793

[underlined: Experimental design]: Groups of 30 female CFT-Wistar rats received gavage doses of heptachlor in groundnut oil for 14 days (presumably 7 days/week). The total administered doses were 25 and 50 mg/kg body weight; the daily doses were 1.8 and 3.6 mg/kg/day; a vehicle control group was also used. After 14 days of exposure, the animals were mated with controls.

[underlined: Effect noted in study and corresponding doses]: A significant decrease in the number of pregnant females (56.3 and 44.4%) and increase in the number of resorptions (18.90 and 11.40%) were observed in both groups of heptachlor-exposed rats. Significant decreases in estradiol-17beta and progesterone levels were also observed in the 1.8 mg/kg/day group. No alterations in the number of implantations were observed. The investigators noted that focal necrosis was observed in the liver; however, they did not note at which dose level and no incidence data were provided.

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a serious LOAEL of 1.8 mg/kg/day for reproductive effects.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]: 1,000

- [X] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Modifying Factor used in MRL derivation]: 3

- [X] 3 for use of a serious end point

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Several targets of toxicity have been identified, in addition to the impaired reproductive performance observed in the Amita Rani and Krishnakumari (1995) study. These include the liver, nervous system, and developing offspring. Gestational exposure to 4.5 or 6.8 mg/kg/day resulted in decreases in pup body weight (Narotsky and Kavlock 1995; Narotsky et al. 1995) and a decrease in pup righting reflex was observed at 4.2 mg/kg/day (Purkerson-Parker et al. 2001b). At twice these dose levels, an increase in pup mortality was observed (Narotsky et al. 1995; Purkerson-Parker et al. 2001b). Liver effects were observed at doses similar to those resulting in developmental effects. Increases in serum alanine aminotransferase and aldolase activity levels, hepatocytomegaly, and minimal monocellular necrosis were observed in rats administered 7 mg/kg/day heptachlor in oil for 14 days (Berman et al. 1995; Krampl 1971). Exposure to 7 mg/kg/day also resulted in excitability and increased arousal in rats administered heptachlor in oil via gavage for 1 or 14 days (Moser et al. 1995).

[underlined: Agency Contacts (Chemical Managers)]: Zemoria Rosemond, B.A.; G. Daniel Todd, Ph.D.; Malcolm Williams, D.V.M., Ph.D.

## Heptachlor Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Heptachlor
CAS Numbers: | 76-44-8
Date: | June 2007
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 49
Species: | Rat

[underlined: Minimal Risk Level]: 0.0001 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Smialowicz RJ, Williams WC, Copeland CB, 2001. The effects of perinatal/juvenile heptachlor exposure on adult immune and reproductive system function in rats. Toxicol Sci 61(1):164–175.11294987

Moser VC, Shafer TJ, Ward TR, 2001. Neurotoxicological outcomes of perinatal heptachlor exposure in the rat. Toxicol Sci 60(2):315–326.11248144

[underlined: Experimental design]: Groups of 15–20 pregnant Sprague Dawley rats were administered via gavage 0, 0.03, 0.3, or 3 mg/kg/day heptachlor in corn oil on gestational day 12 through postnatal day 7; pups were also exposed from postnatal day 7 to 21 or 42. Neurobehavorial assessment consisted of righting reflex on postnatal days 2–5, functional observational battery test, motor activity, passive avoidance test of learning and memory, and Morris water maze to assess spatial and working memory. The liver, kidneys, adrenals, thymus, spleen, ovaries, uterus/vagina, testes, epididymides, seminal vesicles/coagulating glands, and ventral and dorsolateral prostate were histologically examined in 15–17 offspring from each group on postnatal day 46. The following immunological tests were performed in the 8-week-old offspring: splenic lymphoproliferative (LP) responses to T cell mitogens (e.g., concanavalin A [ConA], phytohemagglutinin [PHA]) and to allogeneic cells in a mixed lymphocyte reaction, primary IgM antibody response to sheep red blood cells, examination of splenic lymphocytes subpopulations, and delayed-type and contact hypersensitivity. Reproductive assessment included evaluation of vaginal opening (index of female puberty) and prepuce separation (index of male puberty) beginning at postnatal days 25 and 35, respectively. The offspring were mated with an untreated mate and the dams were allowed to rear the first litter to postnatal day 10. The results of the neurobehavioral assessment were reported by Moser et al. (2001); the remaining results were reported by Smialowicz et al. (2001).

[underlined: Effect noted in study and corresponding doses]: No significant alterations in maternal body weight, number of dams delivering litters, litter size, or pup survival were observed. Additionally, no alterations in pup growth rates, age at eye opening, anogenital distance, or age at vaginal opening or preputial separation were observed. A significant decrease in pup body weight at postnatal day 1 was observed at 3 mg/kg/day; this effect was not observed at postnatal days 7, 14, or 21. No consistent, statistically significant alterations in offspring body weights were observed at postnatal days 21, 28, 35, or 42. Significant alterations in absolute and relative liver weights were observed in males and females exposed to 3 mg/kg/day; increases in absolute and relative ovary weights were also observed at 3 mg/kg/day. No histological alterations were observed in the examined tissues. No alterations in fertility were observed in the adult males and females mated to untreated partners, and no effects on soft tissue or gross body structure of the offspring (F_2_ generation) were observed. No alterations in sperm count or sperm motility were observed.

Righting was significantly delayed in the female offspring of rats exposed to 3 mg/kg/day heptachlor; no significant alterations were observed in the male offspring. The investigators suggested that this was due to a delay in the ontogeny of righting rather than an inability to perform the task. The following significant alterations in the FOB and motor activity tests were found in the offspring dosed until postnatal day 21: increased open field activity in 3 mg/kg/day males, non-dose-related increased activity in figure-eight chambers in females (significant only in 0.03 mg/kg/day group), and faster decline in habituation of activity in 3 mg/kg/day males. Alterations in the offspring dosed until postnatal day 42 included: increased levels of urination in males in the 0.03 and 0.3 mg/kg/day groups, increased landing foot splay in males in the 0.03 mg/kg/day group, and removal reactivity in males and females in the 0.03 mg/kg/day group. No alterations in the passive avoidance test were observed in the offspring exposed until postnatal day 21; in those exposed until postnatal day 42, an increase in the number of nose pokes was observed in all groups of females. No significant alterations in performance on the water maze test were found in the offspring exposed until postnatal day 21. In those exposed until postnatal day 42, increases in latency to find the platform were observed in males and females exposed to 3 mg/kg/day and increases in the time spent in the outer zone were found in males exposed to 0.3 or 3 mg/kg/day. In the water maze memory trial, no differences in performance were found between controls and animals exposed until postnatal day 21. Alterations in significant quadrant bias were observed in 0.03, 0.3, and 3 mg/kg/day males during the first probe test and in 0.3 and 3 mg/kg/day males and 3 mg/kg/day females in the second probe test. The study investigators noted that the heptachlor-exposed rats did not develop an efficient search strategy for locating the platform; they spent more time circling the outer zone of the tank. By the second week of the test, control rats had learned to venture into the zone where the platform was located.

A dose-related, statistically significant suppression of primary IgM antibody response to sRBC was found in males, but not females. The primary IgM response to sRBCs was reduced in 21-week-old males exposed to 0.3 mg/kg/day. A second immunization with sRBCs administered 4 weeks later resulted in a significant reduction in IgG antibody response in males administered 0.03, 0.3, or 3 mg/kg/day heptachlor; no response was seen in females. A decrease in the OX12^+^OX19^−^ (i.e., B/plasma cells) population was also found in the spleen of males exposed to 3 mg/kg/day. No alterations in the following immunological parameters assessed at 8 weeks of age were found: lymphoid organ weights, splenic NK cell activity, splenic cellularity or cell viability, and lymphoproliferative responses of splenic lymphocytes to T-cell mitogens ConA and PHA or to allogenic cells in the mixed lymphocyte reaction. The results of this portion of the study suggest that exposure to heptachlor adversely affects the development of the immune system.

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a minimal LOAEL of 0.03 mg/kg/day for developmental immunological and neurological effects. The observed alterations were considered to be minimally adverse and suggestive of immunotoxicity and neurotoxicity.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The results of the Smialowicz et al. (2001) study suggest that exposure to heptachlor adversely affects the development of the immune system. A framework for testing a chemical’s potential to induce developmental immunotoxicological effects has not been established. Based on the results of studies in mature animals (Luster et al. 1992), two panels of government, industry, and academia immunotoxicology experts (Holsapple et al. 2005; Luster et al. 2003) reached a consensus that assays measuring the response to a T-cell dependent antigen (e.g., sheep red blood cells) should be included in included in a developmental immunotoxicology protocol. In mature animals, the sheep red blood cells antibody plague-forming cell test was the most reliable single test predictor of immunotoxicity (Luster et al. 1992).

Intermediate-duration oral exposure studies have identified a number of targets of heptachlor toxicity including the liver, nervous system, reproductive system, and the developing offspring. Other less documented effects have also been observed. The developing organism appears to be the most sensitive target. In the absence of maternal toxicity, heptachlor is not associated with alterations in pup mortality or body weight gain (Lawson and Luderer 2004; Purkerson-Parker et al. 2001b; Smialowicz et al. 2001) or alterations in the development of the reproductive system (Lawson and Luderer 2004; Smialowicz et al. 2001). In contrast, heptachlor appears to adversely affect the development of the nervous and immune systems. The observed effects include impaired spatial memory at 0.03 mg/kg/day and higher (Moser et al. 2001), impaired spatial learning at 0.3 mg/kg/day and higher (Moser et al. 2001), and decreased in righting reflex (Moser et al. 2001; Purkerson-Parker et al. 2001b) and increased open field activity (Moser et al. 2001) at 3 mg/kg/day. These effects were observed in rats exposed in utero, during lactation, and postnatally until day 42; spatial memory and learning were not adversely affected when the exposure was terminated at postnatal day 21 (Moser et al. 2001). The conflicting results may have resulted in the higher heptachlor epoxide body burden in rats exposed to postnatal day 42, testing at different ages, or exposure may have occurred during a critical window of vulnerability. The effects observed in rats are consistent with those observed in humans. Impaired performance on several neurobehavioral tests, including abstract concept formation, visual perception, and motor planning, was observed in high school students presumably prenatally exposed to heptachlor from contaminated milk products (Baker et al. 2004b). Alterations in immune function were also observed in the rats exposed until postnatal day 42. At 0.03 mg/kg/day and higher, suppression of the immune response to sheep red blood cells was observed (Smialowicz et al. 2001). A reduction in the percentage of B lymphocytes was also observed in the spleen of rats exposed to 3 mg/kg/day. Other tests of immune function were not significantly altered.

The liver effects observed in rats or mice exposed to heptachlor in the diet include increased liver weights (Izushi and Ogata 1990; Pelikan 1971), increased serum alanine aminotransferase levels (Izushi and Ogata 1990), steatosis (Pelikan 1971), and hepatitis and necrosis (Akay and Alp 1981). The lowest LOAEL values for these effects range from 5 to 8.4 mg/kg/day. Neurological signs such as hyperexcitability, seizures, and difficulty standing, walking, and righting were observed at similar dose levels; LOAELs ranged from 1.7 to 17 mg/kg/day (Akay and Alp 1981; Aulerich et al. 1990; Crum et al. 1993). The reproductive system appeared to be more sensitive to heptachlor toxicity. Decreases in epididymal sperm count were observed in rats administered 0.65 mg/kg/day heptachlor in groundnut oil for 70 days (Amita Rani and Krishnakumari 1995). This dose also resulted in increased resorptions when the exposed males were mated with unexposed females. Infertility was observed in all mice exposed to 8.4 mg/kg/day heptachlor for 10 weeks (Akay and Alp 1981).

[underlined: Agency Contacts (Chemical Managers)]: Zemoria Rosemond, B.A.; G. Daniel Todd, Ph.D.; Malcolm Williams, D.V.M., Ph.D.