# 9 REFERENCES

* Not cited in text

Aaron CK, Howland MA. 1998. Insecticides: Organophosphates and carbamates. In: Goldfrank LR, Flomenbaum NE, Lewin NA, , eds. Goldfrank's toxicologic emergencies. 6th ed. Stamford, CT: Appleton & Lange, 1429–1449.
ACGIH. 2007. Azinphos-methyl. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 13, 98.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 2003. Toxicological profile for malathion. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxprofiles/tp154.pdf. August 11, 2006.
Akgür SA, Ozturk P, Sozmen EY, 1999. Paraoxonase and acetylcholinesterase activities in humans exposed to organophosphorus compounds. J Toxicol Environ Health A 58(8):469–474.10632139
Al-Adil KM, White ER, Winterlin WL, 1973. Uptake and translocation of guthion by beans and barley. J Agric Food Chem 21(3):376–379.4708798
Alam MT, Kasatiya SS. 1976. Cytological effects of an organic phosphate pesticide on human cells in vitro. Can J Genet Cytol 18:655–671.
Alam MT, Corbeil M, Chagnon A, 1974. Chromosomal anomalies induced by the organic phosphate pesticide guthion in Chinese hamster cells. Chromosoma 49(1):77–86.4448111
Albright R, Johnson N, Sanderson TW. 1974. Pesticide residues in the top soil of five west Alabama counties. Bull Environ Contam Toxicol 12:378–384.4139997
Allen TR, Janiak T, Frei T, 1990. 52-Week oral toxicity (feeding) study with azinphos-methyl (E 1582) in the dog. Mobay Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41804801.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ III, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson P, Jack R, Burke C, 2004. Surface water monitoring program for pesticides in salmonid-bearing streams, April to December 2003. A cooperative study conducted by the Washington State departments of ecology and agriculture. Olympia, WA: Washington State Department of Agriculture. http://www.ecy.wa.gov/biblio/0403048.htm. August 08, 2006.
Aprea C, Sciarra G, Sartorelli P, 1994. Biological monitoring of exposure to organophosphorus insecticides by assay of urinary alkylphosphates: Influence of protective measures during manual operations with treated plants. Int Arch Occup Environ Health 66:333–338.7896418
Astroff AB, Young AD. 1998. The relationship between maternal and fetal effects following maternal organophosphate exposure during gestation in the rat. Toxicol Ind Health 14(6):869–889.9891917
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 85:60–201.
Auditore JV, Hartmann RC. 1959. Paroxysmal nocturnal hemoglobinuria—II. Erythrocyte acetylcholinesterase defect. Am J Med 27:401–410.13795054
Baker LW, Fitzell DL, Seiber JN, 1996. Ambient air concentrations of pesticides in California. Environ Sci Technol 30:1365–1368.
Bardin PG, Van Eeden SF. 1990. Organophosphate poisoning: Grading the severity and comparing treatment between atropine and glycopyrrolate. Crit Care Med 18(9):956–960.2394119
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bason CW, Colborn T. 1992. US application and distribution of pesticides and industrial chemicals capable of disrupting endocrine and immune systems. In: Colborn T, Clement C, eds. Advances in modern environmental toxicology. Princeton, NJ: Princeton Scientific Publishing Co., 335–345.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bianchi-Santamaria A, Gobbi M, Cembran M, 1997. Human lymphocyte micronucleus genotoxicity test with mixtures of phytochemicals in environmental concentrations. Mutat Res 388(1):27–32.9025789
Brimijoin S, Koenigsberger C. 1999. Cholinesterases in neural development: New findings and toxicologic implications. Environ Health Perspect Suppl 107(1):59–64.
Buratti FM, Volpe MT, Meneguz A, 2003. CYP-specific bioactivation of four organophosphorothioate pesticides by human liver microsomes. Toxicol Appl Pharmacol 186(3):143–154.12620367
Burke C, Anderson P, Cowles J, 2005. Surface water monitoring program for pesticides in salmonid-bearing streams, April through October, 2004. A cooperative study by the Washington State departments of ecology and agriculture. Olympia, WA: Washington State Department of Agriculture. www.ecy.wa.gov/biblio/0503025.html. August 08, 2006.
Bush PB, Neary DG, Taylor JW, 1986. Effects of insecticide use in a pine seed orchard on pesticide levels in fish. Water Resour Bull 22(5):817–827.
California EP A. 1995. Sampling for pesticide residues in California well water, 1995 update of the well inventory database, for sampling results reported from July 1, 1994 to June 30, 1995. Sacramento: California Environmental Protection Agency, Department of Pesticides Regulation. http://www.cdpr.ca.gov/docs/empm/pubs/ehapreps/e9506.htm. May 05, 2006.
California EPA. 2004. Azinphos-methyl (guthion). Risk characterization document (revision no. 1). California Environmental Protection Agency. http://www.cdpr.ca.gov/docs/risk/rcd/azmrcdre.pdf. May 05, 2006.
Carere A, Ortali VA, Cardamone G, 1978. Mutagenicity of dichlorvos and other structurally related pesticides in Salmonella and Streptomyces. Chem Biol Interact 22(2–3):297–308.699179
Carlton FB, Simpson WM, Haddad LM. 1998. The organophosphates and other insecticides. In: Haddad LM, Shannon MW, Winchester JF, eds. Clinical management of poisoning and drug overdose. 3rd ed. Philadelphia, PA: W B Saunders Company, 836–845.
Carrier G, Brunet RC. 1999. A toxicokinetic model to assess the risk of azinphosmethyl exposure in humans through measures of urinary elimination of alkylphosphates. Toxicol Sci 47:23–32.10048150
CDC. 2005. Third national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention, U.S. Department of Health and Human Services. NECH Pub No. 050–0570.
CDPR. 2006. Summary of pesticide use report data. 2004. Sacramento, CA: California Environmental Protection Agency. Department of Pesticide Regulation. http://www.cdpr.ca.gov/. August 10, 2006.
Chen HH, Sirianni SR, Huang CC. 1982a. Sister chromatid exchanges in Chinese hamster cells treated with seventeen organophosphorus compounds in the presence of a metabolic activation system. Environ Mutagen 4:621–624.7140680
Chen HH, Sirianni SR, Huang CC. 1982b. Sister-chromatid exchanges and cell-cycle delay in Chinese hamster V79 cells treated with 9 organophosphorus compounds (8 pesticides and 1 defoliant). Mutat Res 103(3–6):307–313.6211614
Chou C, Williams-Johnson M. 1998. Health effects classification and its role in the derivation of minimal risk levels: Neurological effects. Toxicol Ind Health 14(3):455–471.9569449
Chukwudebe A, March RB, Othman M, 1989. Formation of trialkyl phosphorothioate esters from organophosphorus insecticides after exposure to either ultraviolet light or sunlight. J Agric Food Chem 37:539–545.
Clark JM, Marion JR, Tessier DM, 1991. Airborne drift residues collected near apple orchard environments due to application of insecticide mixtures. Bull Environ Contam Toxicol 46:829–836.1863790
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Costa LG, Li WF, Richter RJ, 1999. The role of paroxonase (PON1) in the detoxication of organophosphates and its human polymorphism. Chem Biol Interact 119–120:429–438.
Costa LG, Schwab BW, Murphy SD. 1982. Tolerance to anticholinesterase compounds in mammals. Toxicology 25:79–97.6760465
Coupe RH, Manning MA, Foreman WT, 2000. Occurrence of pesticides in rain and air in urban and agricultural areas of Mississippi, April-September 1995. Sci Total Environ 248(2–3):227–240.10805242
Coye MJ, Barnett PG, Midtling JE, 1987. Clinical confirmation of organophosphate poisoning by serial cholinesterase analyses. Arch Intern Med 147:438–442.3827420
Curl CL, Fenske RA, Kissel JC, 2002. Evaluation of take-home organophosphorus pesticide exposure among agricultural workers and their children. Environ Health Perspect 110(12):A787–A792.12460819
Dahm PA, Kopecky BE, Walker CB. 1962. Activation of organophosphorus insecticides by rat liver microsomes. Toxicol Appl Pharmacol 4:683–696.14024649
Danis T, Sakkas V, Stratis I, 2002. Pesticide multiresidue analysis in fresh and canned peaches using solid phase extraction and gas chromatography techniques. Bull Environ Contam Toxicol 69:674–681.12375116
Dean A, Pugh J, Embrey K, 1984. Organophosphate insecticide poisoning among siblings— Mississippi. MMWR 33:592–594.6434935
De Peyster A, Willis WO, Molgaard CA, 1993. Cholinesterase and self-reported pesticide exposure among pregnant women. Arch Environ Health 48:348–352.8215600
Diaz Diaz R, Gaggi C, Sanchez-Hernandez JC, 1995. The role of soil and active ingredient properties in degradation of pesticides: A preliminary assessment. Chemosphere 30(12):2375–2386.
Doctor BP, Toker L, Roth E, 1987. A microtiter assay for acetylcholinesterase. Anal Chem 166:399–403.
DOT. 2005. Purpose and use of hazardous materials table. List of marine pollutants. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, Appendix B. http://a257.g.akamaitech.net/7/257/2422/09nov20051500/edocket.access.gpo.gov/cfr_2005/octqtr/pdf/ 49cfr172.101.pdf. January 08, 2008.
DuBois KP, Thursh DR, Murphy SD. 1957. Studies on the toxicity and pharmacologic actions of the dimethoxy ester of benzotriazine dithiophosphoric acid (DBD, guthion). J Pharmacol Exp Ther 119:208–218.13417070
Dubrovsky NM, Kratzer CR, Panshin SY, 2000. Pesticide transport in the San Joaquin River basin. In: Steinheimer T, Ross L, Spittler T, eds. Agrochemical fate and movement. Washington, DC: American Chemical Society, 306–322.
Ecobichon DJ. 1995. Toxic effects of pesticides. In: Klaassen CD, Amdur MO, Doull J, eds. Casarett and Doull's toxicology: The basic science of poisons. 5th ed. New York, NY: McGraw-Hill Companies, Inc, 643–689.
Ellman GL, Courtney KD, Valentino AJ, 1961. A new rapid colormetric determination of acetylcholinesterase activity. Biochem Pharmacol 7:88–95.13726518
EPA. 1978a. Teratology and acute toxicology of selected chemical pesticides administered by inhalation. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Health Effects Research Laboratory. EPA600178003. PB277077.
*EPA. 1978b. Teratology of guthion. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600178056. PB288457.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
*EPA. 1991a. Memorandum. Azinphos-methyl. Review of a chronic feeding/carcinogenicity study in rats. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/foia/reviews/058001.htm. March 20, 2006.
*EPA. 1991b. Memorandum. Azinphos-methyl. One-generation rat reproductive study (83–4) section 6 (a) (2). Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/foia/reviews/058001.htm. March 20, 2006.
*EPA. 1992a. Azinphos-methyl. One-year dog feeding study. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/foia/reviews/058001.htm. March 20, 2006.
EPA. 1992b. Pesticides in ground water database-A complilation of monitoring studies: 1971–1991. Washington, DC: U.S. Environmental Protection Agency. EPA7341292001.
EPA. 1994a. Method 3541: Automated soxhlet extraction. In: SW-846 on-line. U.S. Environmental Protection Agency. Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/3541.pdf. April 10, 2006.
EPA. 1994b. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066F.
EPA. 1996a. Method 3510C: Separatory funnel liquid-liquid extraction. In: SW-846 on-line. U.S. Environmental Protection Agency. Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/3510c.pdf. April 10, 2006.
EPA. 1996b. Method 3540C: Soxhlet extraction. U.S. Environmental Protection Agency. In: SW-846 on-line. U.S. Environmental Protection Agency. Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/3540c.pdf. April 10, 2006.
EPA. 1996c. Method 3550B: Ultrasonic extraction. In: SW-846 on-line. U.S. Environmental Protection Agency. Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/3550b.pdf. April 10, 2006.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998a. Method 3545A: Pressurized fluid extraction (PFE). In: Draft update IVA of SW-846 online. U.S. Environmental Protection Agency. Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/3545a.pdf. April 10, 2006.
EPA. 1998b. Method 8270D: Semivolatile organic compounds by gas chromatography/mass spectrometry (GC/MS). In: Draft update IVA of SW-846 on-line. U.S. Environmental Protection Agency. Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/8270d.pdf. April 10, 2006.
EPA. 1998c. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics.
EPA. 1999a. Environmental fate and effects risk assessment. Azinphos-methyl. Washington, DC: U.S. Environmental Protection Agency. www.epa.gov/oppsrrd1/op/azm.htm. April 10, 2006.
EPA. 1999b. Human health risk assessment. Azinphos-methyl. U.S. Environmental Protection Agency. Office of Pesticide Programs.
EPA. 2000a. Method 3546: Microwave extraction. In: Draft update IVB of SW-846 on-line. U.S. Environmental Protection Agency. Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/3546.pdf. April 10, 2006.
EPA. 2000b. Method 8141B: Organophosphorus compounds by gas chromatography. In: Draft update IVB of SW-846 on-line. U.S. Environmental Protection Agency. Office of Solid Waste. http://www.epa.gov/epaoswer/hazwaste/test/pdfs/8141b_ivb.pdf. April 10, 2006.
*EPA. 2001a. Consolidated list of chemicals subject to the Emergency Planning and Community Right-to-Know Act (EPCRA) and Section 112(r) of the Clean Air Act. U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response. EPA550B01003.
EPA. 2001b. Interim reregistration eligibility decision for azinphos-methyl. Case no. 0235. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppsrrd1/REDs/azinphosmethyl_ired.pdf. April 07, 2006.
EPA. 2002. Organophosphate pesticides: Revised cumulative risk assessment. U.S. Environmental Protection Agency. http://www.epa.gov/pesticides/cumulative/rra-op/. March 10, 2006.
EPA. 2003. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F03016. http://www.epa.gov/safewater/mcl.html. March 07, 2006.
*EPA. 2004a. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R04005. http://epa.gov/waterscience/criteria/drinking/. March 07, 2006.
EPA. 2004b. Guthion. Order denying objections to issuance of tolerance. U.S. Environmental Protection Agency. Fed Regist 69:30042. http://www.gpoaccess.gov/fr/index.html. March 08, 2006.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006a. Acute Exposure Guideline Levels (AEGLs). Washington, DC: Office of Pollution Prevention and Toxics. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/chemlist.htm. March 14, 2006.
EPA. 2006b. Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/ 40cfr116.4.pdf. January 8, 2008.
EPA. 2006c. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. March 07, 2006.
EPA. 2006d. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 8, 2008.
EPA. 2006e. Pesticides classified for restricted use. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 152.175. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 07, 2006.
EPA. 2006f. Table 117.3. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/ 40cfr117.3.pdf. January 08, 2008.
EPA. 2006g. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/ 40cfr302.4.pdf. January 08, 2008.
EPA. 2006h. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2006i. Tolerances and exemptions from tolerances for pesticide chemicals in food. Guthion. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.154. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2006j. Azinphos-methyl; order to amend registrations to terminate certain uses. U.S. Environmental Protection Agency. Fed Regist 71(60):15731–15732.
EPA. 2006k. Azinphosmethyl. Modernized STORET system: Regular results by geographic location (stormodb): Characteristic search by CAS number. U.S. Environmental Protection Agency. http://www.epa.gov/storet/dbtop.html. April 10, 2006.
EPA. 2006l. Proposed phaseout of pesticide azinphos-methyl and longer restricted entry intervals for phosmet. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppsrrd1/op/azm/phaseout_fs.htm. August 08, 2006.
EPA. 2006m. 2006 Edition of the drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. http://www.epa.gov/waterscience/criteria/drinking/dwstandards.pdf. April 11, 2007.
EPA. 2007. Azinphos-methyl; notice of receipt of requests to terminate uses and voluntarily cancel pesticide registrations. U.S. Environmental Protection Agency. Fed Regist 72(152):44511–44514. http://www.epa.gov/EPA-PEST/2007/August/Day-08/p15245.htm. June 09, 2008.
Evans RT, Wroe JM. 1980. Plasma cholinesterase changes during pregnancy. Anaesthesia 35:651–654.7435932
Evans RT, O'Callaghan J, Norman A. 1988. A longitudinal study of cholinesterase changes in pregnancy. Clin Chem 34(11):2249–2252.3180418
Fakhr IM, Zayed SM, Hamdy NA. 1996. Fate and metabolism of radiolabeled insecticide azinphosmethyl in rat. J Pestic Sci 21(1):1–5.
Fazekas GI. 1971. [Macroscopic and microscopic changes in Wofatox (methyl parathion) poisoning]. Zeitschift fur Rechtsmedizin 68:189–194. (German)
Fazekas GI, Rengei B. 1964. [Lethal "Wofatox" intoxication]. Orvosi Hetilap 105:2335–2335. (Hungarian)14228966
FDA. 2003. Food and Drug Administration total diet study. Summary of residues found ordered by pesticide market baskets 91–3–01–4. U.S. Food and Drug Administration. http://www.cfsan.fda.gov/~acrobat/tds1byps.pdf. March 23, 2006.
FDA. 2005. Beverages. Bottled water. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://a257.g.akamaitech.net/7/257/2422/01apr20051500/edocket.access.gpo.gov/cfr_2005/aprqtr/pdf/ 21cfr165.110.pdf. January 08, 2008.
FEDRIP. 2006. Guthion. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Feldmann RJ, Maibach HJ. 1974. Percutaneous penetration of some pesticides and herbicides in man. Toxicol Appl Pharmacol 28:126–132.4853576
*Fenske RA, Curl CL, Kissel JC. 2003. The effect of the 14-day agricultural restricted entry interval on azinphosmethyl exposures in a group of apple thinners in Washington state. Regul Toxicol Pharmacol 38(1):91–97.12878058
Fenske RA, Kissel JC, Lu C, 2000a. Biologically based pesticide dose estimates for children in an agricultural community. Environ Health Perspect 108(6):515–520.10856024
*Fenske RA, Lu C, Simcox NJ, 2000b. Strategies of assessing children's organophosphorus pesticide exposures in agricultural communities. J Expo Anal Environ Epidemiol 10:662–671.11138658
Floesser-Mueller H, Schwack W. 2001. Photochemistry of organophosphorus insecticides. Rev Environ Contam Toxicol 172:129–228.
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Foreman WT, Majewski MS, Goolsby DA, 2000. Pesticides in the atmosphere of the Mississippi River Valley, part II- air. Sci Total Environ 248:213–216.10805241
Franklin CA, Fenske RA, Greenhalgh R, 1981. Correlation of urinary pesticide metabolite excretion with estimated dermal contact in the course of occupational exposure to guthion. J Toxicol Environ Health 7(5):715–731.7265305
Franklin CA, Greenhalgh R, Mailbach HI. 1983. Pesticide chemistry, human welfare and the environment: Proceedings of the 5th International Congress of Pesticide Chemistry, Kyoto, Japan. New York, NY: Pergamon Press.
Franklin CA, Muir NI, Moody RP. 1986. The use of biological monitoring in the estimation of exposure during the application of pesticides. Toxicol Lett 33:127–136.3095958
Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–99.13825957
Gamon M, Saez E, Gil J, 2003. Direct and indirect exogenous contamination by pesticides of rice-farming soils in a Mediterranean wetland. Arch Environ Contam Toxicol 44:141–151.12520386
García AM, Benavides FG, Fletcher T, 1998. Paternal exposure to pesticides and congenital malformations. Scand J Work Environ Health 24(6):473–480.9988089
Garcia-Lopez JA, Monteoliva M. 1988. Physiological changes in human erythrocyte cholinesterase as measured with the "pH stat". Clin Chem 34(10):2133–2135.3168232
Gawlik BM, Feicht EA, Karcher W, 1998. Application of the European reference soil set (EUROSOILS) to a HPLC-screening method for the estimation of soil adsorption coefficients of organic compounds. Chemosphere 36(14):2903–2919.
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Goldfrank LR, Flomenbaum NE, Lewin NA, , eds. 1998. Guthion. In: Goldfrank's toxicologic emergencies. 6th ed. Stamford, CT: Appleton and Lange, 836–843.
Granovsky AV, Ricaud LR, Bengston RL. 1996. Water quality. Fate of azinphosmethyl in a sugarcane field: Distribution in canopy, soil, and runoff. J Environ Qual 25:1210–1216.
Gruber SJ, Munn MD. 1998. Organophosphate and carbamate insecticides in agricultural waters and cholinesterase (ChE) inhibition in common carp (Cyprinus carpio). Arch Environ Contam Toxicol 35:391–396.9732468
Gunderson EL. 1988. FDA total diet study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1208.3240978
Gunderson EL. 1995. FDA total diet study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J AOAC Int 78(6):1353–1363.8664570
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hansch C, Leo A, Hoekman D, eds. 1995. Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 72.
HazDat. 2008. Guthion. HazDat database: ATSDR’s hazardous substance release and health effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. June 10, 2008.
Hitchcock M, Murphy SD. 1971. Activation of parathion and guthion by mammalian, avian, and piscine liver homogenates and cell fractions. Toxicol Appl Pharmacol 19(1):37–45.4398300
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoffman RS, Capel PD, Larson SJ. 2000. Comparison of pesticides in eight U.S. urban streams. Environ Toxicol Chem 19(9):2249–2258.
Holzum B. 1990. Investigation of inhibition of cholinesterase activity in plasma, erythrocytes and brain in a 1-generation study. Mobay Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41916801.
Howard JK, East NJ, Chaney JL. 1978. Plasma cholinesterase activity in early pregnancy. Arch Environ Health 33(5):277–278.708120
Hrelia P, Morotti M, Scotti M, 1990. Genotoxic risk associates with pesticides: Evidences on short-term tests. Pharmacol Res 22(Supplement 3):93–94.
HSDB. 2008. Azinphos methyl. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 3, 2008.
IARC 2006. Guthion. International agency for research on cancer. http://www.iarc.fr/. June 22, 2006.
IARC. 2007. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–98. (Alphabetical order). International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/Listagentsalphorder.pdf. January 5, 2008.
IRIS. 2008. Guthion. Washington, DC: Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/. June 9, 2008.
Iyaniwura TT. 1991. Relative inhibition of rat plasma and erythrocyte cholinesterases by pesticide combinations. Vet Hum Toxicol 33:166–168.2035247
*Jeang CL, Li GC. 1980. Screening of pesticides for mutagenicity in the microbial system. K'o Hsueh Fa Chan Yueh K'an 8(6):551–559.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Kalow W. 1956. Familial incidence of low pseudocholinesterase levels [Letter]. Lancet 2:576–577.
Kavlock RJ, Chernoff N, Rogers EH. 1985. The effect of acute maternal toxicity on fetal development in the mouse. Teratog Carcinog Mutagen 5:3–13.2859660
Kimmerle G. 1976. Subchronic inhalation toxicity of azinphos-methyl in rats. Arch Toxicol 35(2):83–89.947316
Knaack JB, Maddy KT, Jackson T, 1978. Cholinesterase activity in blood samples collected from field workers and non-field workers in California. Toxicol Appl Pharmacol 45:755–770.725930
Knuth ML, Heinis LJ, Anderson LE. 2000. Persistence and distribution of azinphos-methyl following application to littoral enclosure mesocosms. Ecotoxicol Environ Saf 47(2):167–177.11023695
Koch D, Lu C, Fisker-Andersen J, 2002. Temporal association of children's pesticide exposure and agricultural spraying: Report of a longitudinal biological monitoring study. Environ Health Perspect 110(8):1–7.11781158
Kolpin DW, Barbash JE, Gilliom RJ. 2000. Pesticides in ground water of the United States, 1992–1996. Ground Water 38(6):858–863.
Kolpin DW, Goolsby DA, Thurman EM. 1995. Pesticides in near-surface aquifers: An assessment using highly sensitive analytical methods and tritium. J Environ Qual 24:1125–1132.
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Krapac G, Roy W, Smyth CA, 1995. Occurrence and distribution of pesticides in soil at agrichemical facilities in Illinois. J Soil Contam 4(3):209–226.
Kraus JF, Richards DM, Borhani NO, 1977. Physiological response to organophosphate residues in field workers. Arch Environ Contam Toxicol 5(4):471–485.883852
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ III, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kyriakidis NB, Athanasopoulos PE, Karamanolis T. 2001. Degradation of the insecticide azinphos methyl in orange and peach juices during storage at different temperatures. Food Addit Contam 18(4):309–13.11339265
Lartiges SB, Garrigues PP. 1995. Degradation kinetics of organophosphorus and organonitrogen pesticides in different waters under various environmental conditions. Environ Sci Technol 29:1246–1254.22192018
Layer PG. 1990. Cholinesterase preceding major tracts in vertebrate neurogenesis. Bioessays 12:415–420.2256905
Layer PG, Willbold E. 1994. Cholinesterase in avian neurogenesis. Int Rev Cytol 151:139–181.8014021
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lehmann H, Ryan E. 1956. The familial incidence of low pseudocholinesterase level [Letter]. Lancet 2:124.
Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levine BS, Murphy SD. 1977. Effect of piperonyl butoxide on the metabolism of dimethyl and diethyl phosphorothionate insecticides. Toxicol Appl Pharmacol 40:393–406.882978
Lisi P, Caraffini S, Assalve D. 1987. Irritation and sensitization potential of pesticides. Contact Dermatitis 17:212–218.2962818
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Loewenherz C, Fenske RA, Simcox NJ, 1997. Biological monitoring of organophosphorus pesticide exposure among children of agricultural workers in Central Washington State. Environ Health Perspect 105(12):1–13.
Lu C, Fenske RA, Simcox NJ, 2000. Pesticide exposure of children in an agricultural community: Evidence of household proximity to farmland and take home exposure pathways. Environ Res 84:290–302.11097803
Majewski MS, Foreman WT, Goolsby DA. 2000. Pesticides in the atmosphere of the Mississippi River Valley, part I-rain. Sci Total Environ 248:201–212.10805240
Maroni M, Colosio C, Ferioli A, 2000. Organophosphorous pesticides. Toxicology 143:9–37.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
McCauley LA, Lasarev MR, Higgins G, 2001. Work characteristics and pesticide exposures among migrant agricultural families: A community-based research approach. Environ Health Perspect 109(5):533–538.
McCurdy SA, Hansen ME, Weisskopf CP, 1994. Assessment of azinphosmethyl exposure in California peach harvest workers. Arch Environ Health 49(4):289–296.8031187
Medina D, Prieto A, Ettiene G, 1999. Persistence of organophosphorus pesticide residues in Limon River waters. Bull Environ Contam Toxicol 63:39–44.10423481
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Meylan WM, Howard PH, Boethling RS, 1999. Improved method for estimating bioconcentration/bioaccumulation factor from octanol/water partition coefficient. Environ Toxicol Chem 18(4):664–672.
Midtling JE, Barnett PG, Coye MJ, 1985. Clinical management of field worker organophosphate poisoning. West J Med 142(4):514–518.4013266
Moate TF, Furia M, Curl C, 2002. Size exclusion chromatographic cleanup for GC/MS determination of organophosphorus pesticide residues in household and vehicle dust. J AOAC Int 85(1):36–43.11878617
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Motoyama N, Dauterman WC. 1972. The in vitro metabolism of azinphosmethyl by mouse liver. Pestic Biochem Physiol 2(2):170–177.
Murphy SD, DuBois KP. 1957. Enzymatic conversion of the dimethoxy ester of benzotriazine dithiophosphoric acid to an anticholinesterase agent. J Pharmacol Exp Ther 119(4):572–583.13429466
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NCI. 1978. Bioassay of azinphosmethyl for possible carcinogenicity. Bethesda, MD: National Cancer Institute. NCI-CG-TR-69.
NIOSH. 1981. Occupational health guidelines for azinphos-methyl. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/pdfs/0044.pdf. April 10, 2006.
NIOSH. 1994. Method 5600. Issue 1. Organophosphorus pesticides. NIOSH manual of analytical methods. 4th ed. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/5600.pdf. April 03, 2006.
NIOSH. 2005. Guthion. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. March 08, 2006.
NPIRS. 2006. National Pesticide Information Retrieval System. http://ppis.ceris.purdue.edu/#. April 11, 2006.
NRC. 1977. Azinphosmethyl. Drinking water and health. Washington, DC: National Academy Press, 604–608.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Academy Press, National Research Council.
*NTP. 1978. Bioassay of azinphosmethyl for possible carcinogenicity. Bethesda, MD: National Cancer Institute. National Toxicology Program. NCI-CG-TR-69. http://ntp.niehs.nih.gov/ntp/htdocs/LT_rpts/tr069.pdf. April 10, 2006.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. January 11, 2008.
OSHA. 2005a. Air contaminants. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. March 08, 2006.
OSHA. 2005b. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. March 08, 2006.
OSHA. 2005c. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. March 08, 2006.
Osmundson M. 1998. Insecticides and pesticides. In: Viccellio P, ed. Emergency toxicology. 2nd ed. Philadelphia, PA: Lippincott-Raven Publishers, 401–413.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTABA438.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Pasquet J, Mazuret A, Fournel J, 1976. Acute oral and percutaneous toxicity of phosalane in the rat, in comparison with azinphosmethyl and parathion. Toxicol Appl Pharmacol 37(1):85–92.968909
Pitarch E, Lopez FJ, Serrano R, 2001. Multiresidue determination of organophosphorus and organochlorine pesticides in human biological fluids by capillary gas chromatography. Fresenius J Anal Chem 369:502–509.11336335
Richardson JR, Chambers HW, Chambers JE. 2001. Analysis of the additivity of in vitro inhibition of cholinesterase by mixtures of chlorpyrifos-oxon and azinphos-methyl-oxon. Toxicol Appl Pharmacol 172(2):128–139.11298499
Rider JA, Puletti EJ. 1969. Studies on the anticholinesterase effects of gardona, methyl parathion, and guthion in human subjects [Abstract]. Fed Proc 28(2):479.
Rider JA, Swader JI, Puletti EJ. 1970. Methyl parathion and guthion anticholinesterase effects in human subjects [Abstract]. Fed Proc 29(2):349.
Rider JA, Swader J, Puletti EJ. 1971. Anticholinesterase toxicity studies with methyl parathion, guthion and phosdrin in human subjects [Abstract]. Fed Proc 30(2):443.
Rider JA, Swader JI, Puletti EJ. 1972. Anticholinesterase toxicity studies with guthion, phosdrin, di-syston, and trithion in human subjects [Abstract]. FASEB Monogr 31:520.
Ripley BD, Lissemore LI, Leishman PD, 2000. Pesticide residues on fruits and vegetables from Ontario, Canada, 1991–1995. J AOAC Int 83:196–213.10693021
Sanz P, Rodriguez-Vincente MC, Diaz D, 1991. Red blood cell and total blood acetylcholinesterase and plasma pseudocholinesterase in humans: Observed variances. Clin Toxicol 29(1):81–90.
Sartorelli P, Carboncini F, Murdaca F, 1999. Contact sensitization in fruit farmers. J Environ Med 1:51–53.
Schmidt WM, Chevalier. 1984. R 1582. (Common name: Azinphos-methyl). Study of chronic toxicity and carcinogenicity to Wistar rats. Mobay Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41119901.
Schneider F, Steenland K, Hernandez B, 1994. Monitoring peach harvest workers exposed to azinphosmethyl residues in Sutter County, California, 1991. Environ Health Perspect 102(6–7):207–215.
Schroeder RS. 1992. Dermal absorption of azinphos-methyl by rats from a guthion 35% wettable powder formulation using 14C-azinphos-methyl. Miles Inc. Submitted to the U.S. Environmental Protection Agency: MRID42452701C.
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Sheets LP, Hamilton BF, Sangha GK, 1997. Subchronic neurotoxicity screening studies with six organophosphate insecticides: An assessment of behavior and morphology relative to cholinesterase inhibition. Fundam Appl Toxicol 35:101–119.9024678
Sheridan RS, Meola JR. 1999. Analysis of pesticide residues in fruits, vegetables, and milk by gas chromatography/tandem mass spectrometry. J AOAC Int 82(4):982–990.10444835
Short RD, Minor JL, Lee CC, 1980. Development toxicity of guthion in rats and mice. Arch Toxicol 43(3):177–186.7369866
Simcox NJ, Fenske RA, Wolz SA, 1995. Pesticides in household dust and soil: Exposure pathways for children of agricultural families. Environ Health Perspect 103:1126–1134.8747019
Skinner CS, Kilgore WW. 1982. Acute dermal toxicities of various organophosphate insecticides in mice. J Toxicol Environ Health 9:491–497.7097799
Souza MS, Magnarelli GG, Rovedatti MG, 2005. Prenatal exposure to pesticides: Analysis of human placental acetylcholinesterase, glutathione S-transferase and catalase as biomarkers of effect. Biomarkers 10(5):376–389.16243722
SRI. 2005. Pesticides: Azinphosmethyl. Directory of chemical producers. Menlo Park, CA: Access Intelligence, LLC, 774.
Staiff DC, Comer SW, Armstrong JF, 1975. Persistence of azinophosmethyl in soil. Bull Environ Contam Toxicol 13(3):362–368.1125466
Su MQ, Kinoshita FA, Frawley JP, 1971. Comparative inhibition of aliesterases and cholinesterase in rats fed eighteen organophosphorus insecticides. Toxicol Appl Pharmacol 20:241–249.5133254
Sultatos LG. 1994. Mammalian toxicology of organophosphorus pesticides. J Toxicol Environ Health 43:271–289.7966438
Sultatos LG, Woods L. 1988. The role of glutathione in the detoxification of the insecticides methyl parathion and azinphosmethyl in the mouse. Toxicol Appl Pharmacol 96(1):168–174.3188022
Suntio LR, Shiu WY, Mackay D, 1988. Critical review of Henry's law constants for pesticides. Rev Environ Contam Toxicol 103:1–59.
Tafuri J, Roberts J. 1987. Organophosphate poisoning. Ann Emerg Med 16(2):93–102.
Taylor P. 2001. Anticholinesterase agents. In: Hardman JG, Limbird LE, Gilman AG, eds. The pharmacological basis of therapeutics. 10th ed. New York, NY: McGraw-Hill, 175–191.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Tomlin CD S, ed. 2003. Azinphos-methyl (45). In: e-Pesticide manual. 13th ed. United Kingdom: British Crop Protection Council.
USDA. 2000. Trends in crop pesticide use: Comparing 1992 and 1997. U.S. Department of Agriculture. http://www.ncfap.org/ncfap/trendsreport.pdf. April 11, 2006.
USGS. 1999. Pesticides in streams of the United States. Initial results from the National water-quality assessment program. Sacramento, CA: U.S. Geological Survey. http://ca.water.usgs.gov/pnsp/rep/wrir984222/front.book.pdf. April 11, 2006.
USGS. 2001. Pesticides in surface water of the Yakima River Basin, Washington, 1999–2000. Their occurrence and an assessment of factors affecting concentrations and loads. U.S. Geological Survey. Portland, OR: Water-Resources Investigations Report 01–4211. http://or.water.usgs.gov/pubs_dir/WRIR01-4211/. April 11, 2006.
USGS. 2002. 2002 Pesticide use maps. Azinphos-methyl-insectide. U.S. Geological Survey. http://water.usgs.gov/nawqa/pnsp/usage/maps/show_map.php?year=02&map=m6004. June 09, 2008.
USGS. 2003. Pesticides in surface water of the United States: Table 1. Pesticides in streams at agricultural sites, 1991–2001. Washington, DC: U.S. Geological Survey. http://ca.water.usgs.gov/pnsp/pestsw/Pest-SW_2001_table1_ag.html. March 18, 2006.
USGS. 2006b. Occurance, distribution, and transport of pesticides in agricultural irrigation-return flow from four drainage basins in the Columbia Basin Project, Washington, 2002–2004, and comparison with historical data. Reston, VA: U.S. Geological Survey. http://pubs.usgs.gov/sir/2006/5005/pdf/sir20065005.pdf. December 21, 2007.
USGS. 2006a. The quality of our nation's waters: Pesticides in the nation's streams and ground water, 1992–2001. Reston, VA: U.S. Geological Survey. http://ca.water.usgs.gov/pnsp/pubs/circ1291/. April 11, 2006.
Vasilic Z, Drevenkar V, Frobe Z, 1987. The metabolites of organophosphorus pesticides in urine as an indicator of occupational exposure. Toxicol Environ Chem 14:111–127.
Venkataraman BV, Niyer GY, Narayanan R, 1990. Erythrocyte and plasma cholinesterase activity in normal pregnancy. Indian J Physiol Pharmacol 34:26–28.2361719
Verschueren K, ed. 2001. Azinphosmethyl. Handbook of environmental data on organic chemicals. 4th ed. New York, NY: John Wiley & Sons, Inc., 238–240.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Villa S, Finizio A, Vighi M. 2003. Pesticide risk assessment in a lagoon ecosystem. Part I. Exposure assessment. Environ Toxicol Chem 22(4):928–935.12685731
Vos JG, Krajnc EI, Beekhof PK, 1983. Methods for testing immune effects of toxic chemicals: Evaluation of the immunotoxicity of various pesticides in the rat. In: Miyamoto J, Kearney PC, eds. Pesticide chemistry, human welfare and the environment. Oxford, UK: Pergamon Press, 497–504.
Waters MD, Snadhu SS, Simmon VF, 1982. Study of pesticide genotoxicity. Basic Life Sci 21:275–326.7150196
Weinbaum Z, Schenker MB, Gold EB, 1997. Risk factors for systemic illnesses following agricultural exposures to restricted organophosphates in California, 1984–1988. Am J Ind Med 31(5):572–579.9099360
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. March 08, 2006.
WHO. 2004. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Whyatt RM, Barr DB. 2001. Measurement of organophosphate metabolites in postpartum meconium as a potential biomarker of prenatal exposure: A validation study. Environ Health Perspect 109:417–420.11335191
Widdowson EM, Dickerson JW T. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press, 1–247.
*Wolfe HR, Staiff DC, Armstrong JF, 1973. Persistence of parathion in soil. Bull Environ Contam Toxicol 10(1):1–9.
Woodrow JE, Seiber JN, Baker LW. 1997. Correlation techniques for estimating pesticide volatilization flux and downwind concentrations. Environ Sci Technol 31:523–529.
Worden AN, Wheldon GH, Noel PR, 1973. Toxicity of gusathion for the rat and dog. Toxicol Appl Pharmacol 24(3):405–412.4704814
Yaron B, Bielorai H, Kliger L. 1974. Fate of insecticides in an irrigated field: Azinphosmethyl and tetradifon cases. J Environ Qual 3(4):413–417.
Zeiger E, Anderson B, Haworth S, 1987. Salmonella mutagenicity tests: III. Results from the testing of 255 chemicals. Environ Mutagen 9:1–110.
Zendzian RP. 2003. Pesticide residue on/in the washed skin and its potential contribution to dermal toxicity. J Appl Toxicol 23:121–136.12666157
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372