# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of guthion is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Guthion is a nonsystemic organophosphate insecticide. Pure guthion is a colorless to white, odorless, crystalline solid with a melting point range of 72–74 °C, while the technical-grade material is a cream to yellow-brown, granular solid with a melting point of 67–70 °C (EPA 2001b). Guthion is readily soluble in most organic solvents (acetone, toluene, chloroform, acetonitrile, benzene, xylene, carbon tetrachloride, and chlorobenzene), slightly soluble in methanol, ethanol, and propanol, and poorly soluble in water. Information regarding the physical and chemical properties of this compound is located in Table 4-2.

Table 4-1 Chemical Identity of Guthion

Characteristics | Guthion | References
Chemical name | S-(3,4-Dihydro-4-oxobenzo[d]-[1,2,3]-triazin-3-yl-methyl)O,O-dimethylphosphorodithioate | Tomlin 2003
Synonyms | O,O-Dimethyl S-[(4-oxo-1,2,3-benzotriazin-3(4H)-yl)-methyl]; Azinphos-methyl | Tomlin 2003
Trade names | Guthion; Aziflo; Azin-PB; Crysthyon; Mezyl; Sniper; Supervalex | Tomlin 2003
Chemical formula | C_10_H_12_N_3_O_3_PS_2_ | Tomlin 2003
Chemical structure | [image] | Tomlin 2003
Identification numbers:
CAS registry | 86-50-0 | Tomlin 2003
NIOSH RTECS | TE1925000 | NIOSH 2005
EPA hazardous waste | No data
OHM/TADS | No data
DOT/UN/NA/IMCO shipping | NA 2783; Guthion mixture, liquid | HSDB 2008
HSDB | 1171 | HSDB 2008
NCI | No data

Table 4-2 Physical and Chemical Properties of Guthion

Property | Information | References
Molecular weight | 317.3 | Tomlin 2003
Color | Colorless to white (pure material); cream to yellow brown (technical grade material) | EPA 2001b
Physical state | Crystalline | Tomlin 2003
Melting point | 72–74 °C (pure material); 67–70 °C (technical-grade material) | EPA 2001b
Boiling point | Decomposes above 200 °C | Tomlin 2003
Specific gravity (20 °C) | 1.518 | Tomlin 2003
Odor | Odorless | EPA 2001b
Odor threshold
Water | 0.0002 mg/kg | Verschueren 2001
Air | No data
Solubility
Water at 25 °C | 28 mg/L | Tomlin 2003
Organic solvents | >250 g/L in dichloroethane, acetone, acetonitrile, ethyl acetate, and DMSO; 1.2 g/L in n-heptane and 170 g/L in xylene (all at 20 °C) | Tomlin 2003
Partition coefficients
Log K_ow_ | 2.75 | Hansch et al. 1995
Log K_oc_ | 2.69–3.67 | Gawlik et al. 1998
Vapor pressure
20 °C | 3×10^−5^ Pa (2.2×10^−7^ mm Hg) | Suntio et al. 1988
Henry’s law constant | 3.7×10^−9^ atm-m^3^/mol | EPA 1999a
Flashpoint (closed cup) | No data
Flammability limits
Air | No data
Conversion factors^a^
ppm (v/v to mg/m^3^ in air (20 °C) | 1 ppm = 13.2 mg/m^3^ | Verschueren 2001
mg/m^3^ to ppm (v/v) in air (20 °C) | 1 mg/m^3^ = 0.076 ppm | Verschueren 2001
Explosive limits | No data

a Guthion exists partially in the particulate-phase in the atmosphere. This conversion is only applicable to vapor-phase guthion.