# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99-499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Guthion Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Guthion
CAS Numbers: | 86-50-0
Date: | June 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 3
Species: | Rat

[underlined: Minimal Risk Level]: 0.02 [ ] mg/kg/day [ ] ppm [X] mg/m^3^

[underlined: Reference]: Kimmerle G. 1976. Subchronic inhalation toxicity of azinphos-methyl in rats. Arch Toxicol 35:83–89.

[underlined: Experimental design]: In this study (Kimmerle 1976), groups of 10 male and 10 female SPF Wistar rats were exposed to aerosolized guthion at 0.195, 1.24, or 4.72 mg/m^3^, 6 hours/day, 5 days/week for 12 weeks. Guthion aerosols were generated by first dissolving technical-grade guthion in a 1:1 solution of ethanol/polypropylene glycol. Ninety-seven percent of the droplets had a diameter of 1±0.5 μm. The animals were inspected daily and weighed weekly. Erythrocyte AChE and plasma ChE activities were determined after 2, 4, 6, 8, 10, and 12 weeks and determinations of hematology, serum glutamic-oxalacetic transaminase (SGOT), serum glutamic-pyruvic transaminase (SGPT), alkaline phosphatase, urea, creatinine, and bilirubin were conducted after 12 weeks of exposure. At study termination, animals were sacrificed for gross examination. The thyroid, thymus, heart, lungs, liver, spleen, kidneys, adrenals, and gonads were weighed and examined histologically and brain AChE activity was determined.

[underlined: Effect noted in study and corresponding doses]: There were no significant changes in appearance or behavior of male or female rats. Male rats in the 4.72 mg/m^3^ group showed a 20% reduction in body weight gain during the 12-week exposure period. Although body weight was not reported on week 2, on week 4, body weight gain in male rats in the 4.72 mg/m^3^ group was 60% that in control animals. After 2 weeks of exposure, erythrocyte AChE activity was reduced by 25 and 18% in male and female rats, respectively, in the 4.72 mg/m^3^ group, but not at lower concentrations. There were no biologically significant reductions in plasma ChE activity at any of the doses tested.

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a NOAEL of 1.24 mg/m^3^ and a LOAEL of 4.72 mg/m^3^ for decreased erythrocyte AChE activity after 2 weeks of exposure.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustments
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: As per MRL guidance from ATSDR, a 5–7-day duration adjustment is not conducted for acute inhalation exposures. Thus, the NOAEL of 1.24 mg/m^3^ was adjusted for intermittent exposure (NOAEL_[ADJ]_) as follows:

NOAEL_[ADJ]_ = 1.24 mg/m^3^ x 6 hours/24 hours

NOAEL_[ADJ]_ = 0.31 mg/m^3^

The human equivalent concentration (HEC) of the NOAEL_[ADJ]_ was calculated using the equations below. The RDDR_[ER]_ is the regionally deposited dose ratio for the extrarespiratory effects. It is calculated using EPA’s software (version 2.3) for calculating RDDRs (EPA 1994b) and particle size and body weight data from Kimmerle (1976). A presentation of the equations and assumptions used to calculate the RDDR can be found in EPA (1994b).

NOAEL_[HEC]_ = NOAEL_[ADJ]_ x RDDR_[ER]_

NOAEL_[HEC]_ = 0.31 mg/m^3^ x 1.626

NOAEL_[HEC]_ = 0.50 mg/m^3^

An RDDR_ER_ of 1.626 was estimated using the default parameters and body weight data presented in Table A-1.

Table A-1 Default Parameters Used in the Derivation of RDDR_ER_

Parameter | Humans | Rats
Body weight (kg) | 70.00 | 0.182^a^
Minute volume (L) | 13.80 | 0.139
ET area (cm^2^)^b^ | 200.00 | 15.00
TB area (cm^2^)^c^ | 3,200.00 | 22.50
PU area (m^2^)^d^ | 54.00 | 0.34

a 2-week body weight value estimated from Kimmerle (1976)

b Extrathoracic respiratory tract region

c Tracheobronchial respiratory tract region

d Pulmonary respiratory tract region

RDDR_ER_ = regionally deposited dose ratio for the extrarespiratory effects

Based on the information provided by Kimmerle (1976) it was assumed that the sizes of the aerosol particles were log-normally distributed in a manner such that 1.5% of these were <0.5 μm and 1.5% were >1.5 μm. Based on these assumptions, a geometric mean and geometric standard deviation of 0.9 and 0.23 μm, respectively, were calculated. These values were used to calculate a Mass Median Aerodynamic Diameter (MMAD) of 0.88 μm using the recommended equation in Table H-2 (shown below) of the guidance document Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (EPA 1994b).

MMAD = CMAD e ( 3 [ ln variance ]^2^ )

No conversion is required for the geometric standard deviation and the geometric standard deviation of 0.23 was used. CMAD is the count median aerodynamic diameter (0.9 μm).

The NOAEL_[HEC]_ of 0.50 mg/m^3^ was divided by an uncertainty factor of 30 (3 for extrapolation from animals to humans using dosimetric adjustment and 10 for human variability), resulting in an acuteduration inhalation MRL of 0.02 mg/m^3^. Application of the benchmark dose methodology to the data from Kimmerle (1976) was considered, but the data were presented as means without standard errors or standard deviations. Without these measures, the benchmark dose methodology could not be applied.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes, animals were exposed 6 hours/day, 5 days/week.

NOAEL_[ADJ]_ = 1.24 mg/m^3^ x 6 hours/24 hours

NOAEL_[ADJ]_ = 0.31 mg/m^3^

[underlined: Other additional studies or pertinent information that lend support to this MRL]: EPA (1978a) reported a 41% (range 27–59%) reduction in blood ChE activity in rats exposed to guthion aerosols (39 mg/m^3^) for 1 hour. The consistent observation of reduced ChE activity in the two available inhalation studies is in agreement with the observations made in a number of studies with guthion administered orally to rats and dogs during acute (Astroff and Young 1998; Pasquet et al. 1976), intermediate (Holzum 1990; Sheets et al. 1997), and chronic (Allen et al. 1990; Schmidt and Chevalier 1984) exposures.

[underlined: Agency Contacts (Chemical Managers)]: Nickolette Roney, Selene Chou, Yee-Wan Stevens

## Guthion Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Guthion
CAS Numbers: | 86-50-0
Date: | June 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 7
Species: | Rat

[underlined: Minimal Risk Level]: 0.01 [ ] mg/kg/day [ ] ppm [X] mg/m^3^

[underlined: Reference]: Kimmerle G. 1976. Subchronic inhalation toxicity of azinphos-methyl in rats. Arch Toxicol 35:83–89.

[underlined: Experimental design]: In this study (Kimmerle 1976), groups of 10 male and 10 female SPF Wistar rats were exposed to aerosolized guthion at 0.195, 1.24, or 4.72 mg/m^3^, 6 hours/day, 5 days/week for 12 weeks. Guthion aerosols were generated by first dissolving technical-grade guthion in a 1:1 solution of ethanol/polypropylene glycol. Ninety-seven percent of the droplets had a diameter of 1±0.5 μm (Kimmerle 1976). The animals were inspected daily and weighed weekly. Erythrocyte AChE and plasma ChE activities were determined after 2, 4, 6, 8, 10, and 12 weeks and determinations of hematology, SGOT, SGPT, alkaline phosphatase, urea, creatinine, and bilirubin were conducted after 12 weeks of exposure. At study termination, animals were sacrificed for gross examination. The thyroid, thymus, heart, lungs, liver, spleen, kidneys, adrenals, and gonads were weighed and examined histologically and brain AChE activity was determined.

[underlined: Effect noted in study and corresponding doses]: There were no significant changes in appearance or behavior of male or female rats. Male rats in the 4.72 mg/m^3^ group showed a 20% reduction in body weight gain during the 12-week exposure period. No effects were detected in the examined hematological and serum clinical chemistry parameters. There were no observed differences in absolute or relative organ weights or morphological alterations in organs or tissues in any of the rats. From week 4 to week 12, erythrocyte AChE activity was reduced by 29–48% in male and 26–39% in female rats in the 4.72 mg/m^3^ group. There were no additional reductions in erythrocyte AChE activity beyond week 4. Reductions in erythrocyte AChE activity in rats exposed to guthion doses <4.72 mg/m^3^ were 17% or less and are not considered an adverse effect. The investigator noted that brain ChE activity was not reduced at any of the concentrations tested, but no data were shown.

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a NOAEL of 1.24 mg/m^3^ and LOAEL of 4.72 mg/m^3^ for decreased erythrocyte AChE activity.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans with dosimetric adjustments
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: The NOAEL of 1.24 mg/m^3^ was adjusted for intermittent exposure (NOAEL[ADJ]) as follows:

- NOAEL_[ADJ]_ = 1.24 mg/m^3^ x 6 hours/24 hours x 5 days/7 days
- NOAEL_[ADJ]_ = 0.22 mg/m^3^

The human equivalent concentration (HEC) of the NOAEL_[ADJ]_ was calculated using the equations below. The RDDR_[ER]_ is the regionally deposited dose ratio for the extrarespiratory effects. It is calculated using EPA’s software (version 2.3) for calculating RDDRs (EPA 1994b) and particle size and body weight data from Kimmerle (1976). A presentation of the equations and assumptions used to calculate the RDDR can be found in EPA (1994b).

NOAEL_[HEC]_ = NOAEL_[ADJ]_ x RDDR_[ER]_

NOAEL_[HEC]_ = 0.22 mg/m^3^ x 1.695

NOAEL_[HEC]_ = 0.37 mg/m^3^

An RDDR_ER_ of 1.695 was estimated using the default parameters and body weight data presented in Table A-2.

Table A-2 Default Parameters Used in the Derivation of RDDR_ER_

Parameter | Humans | Rats
Body weight (kg) | 70.00 | 0.253^a^
Minute volume (L) | 13.80 | 0.182
ET area (cm^2^)^b^ | 200.00 | 15.00
TB area (cm^2^)^c^ | 3,200.00 | 22.50
PU area (m^2^)^d^ | 54.00 | 0.34

a 12-week body weight value from Kimmerle (1976)

b Extrathoracic respiratory tract region

c Tracheobronchial respiratory tract region

d Pulmonary respiratory tract region

RDDR_ER_ = regionally deposited dose ratio for the extrarespiratory effects

Based on the information provided by Kimmerle (1976), it was assumed that the sizes of the aerosol particles were log-normally distributed in a manner such that 1.5% of these were <0.5 μm and 1.5% were >1.5 μm. Based on these assumptions, a geometric mean and geometric standard deviation of 0.9 and 0.23 μm, respectively, were calculated. These values were used to calculate a MMAD of 0.88 μm using the recommended equation in Table H-2 of the guidance document Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (EPA 1994b).

MMAD = CMAD e ( 3 [ ln variance ]^2^ )

No conversion is required for the geometric standard deviation and the geometric standard deviation of 0.23 was used. CMAD is the count median aerodynamic diameter (0.9 μm).

The NOAEL_[HEC]_ of 0.37 mg/m^3^ was divided by an uncertainty factor of 30 (3 for extrapolation from animals to humans using dosimetric adjustment and 10 for human variability), resulting in an intermediate-duration inhalation MRL of 0.01 mg/m^3^. Application of the benchmark dose methodology to the data from Kimmerle (1976) was considered, but the data were presented as means without standard errors or standard deviations. Without these measures, the benchmark dose methodology could not be applied.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes, animals were exposed 6 hours/day, 5 days/week.

NOAEL_[ADJ]_ = 1.24 mg/m^3^ x 6 hours/24 hours x 5 days/7 days

NOAEL_[ADJ]_ = 0.22 mg/m^3^

[underlined: Other additional studies or pertinent information that lend support to this MRL]: EPA (1978a) reported a 41% (range 27–59%) reduction in blood ChE activity in rats exposed to guthion aerosols (39 mg/m^3^) for 1 hour. The consistent observation of reduced ChE activity in the two available inhalation studies is in agreement with the observations made in a number of studies with guthion administered orally to rats and dogs during acute (Astroff and Young 1998; Pasquet et al. 1976), intermediate (Holzum 1990; Sheets et al. 1997), and chronic (Allen et al. 1990; Schmidt and Chevalier 1984) exposures.

[underlined: Agency Contacts (Chemical Managers)]: Nickolette Roney, Selene Chou, Yee-Wan Stevens

## Guthion Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Guthion
CAS Numbers: | 86-50-0
Date: | June 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [X] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 7
Species: | Rat

[underlined: Minimal Risk Level]: 0.01 [ ] mg/kg/day [ ] ppm [X] mg/m^3^

[underlined: Reference]: Kimmerle G. 1976. Subchronic inhalation toxicity of azinphos-methyl in rats. Arch Toxicol 35:83–89.

[underlined: Experimental design]: In this study (Kimmerle 1976), groups of 10 male and 10 female SPF Wistar rats were exposed to aerosolized guthion at 0.195, 1.24, or 4.72 mg/m^3^, 6 hours/day, 5 days/week for 12 weeks. Guthion aerosols were generated by first dissolving technical-grade guthion in a 1:1 solution of ethanol/polypropylene glycol. Ninety-seven percent of the droplets had a diameter of 1±0.5 μm (Kimmerle 1976). The animals were inspected daily and weighed weekly. Erythrocyte AChE and plasma ChE activities were determined after 2, 4, 6, 8, 10, and 12 weeks and determinations of hematology, SGOT, SGPT, alkaline phosphatase, urea, creatinine, and bilirubin were conducted after 12 weeks of exposure. At study termination, animals were sacrificed for gross examination. The thyroid, thymus, heart, lungs, liver, spleen, kidneys, adrenals, and gonads were weighed and examined histologically and brain AChE activity was determined.

[underlined: Effect noted in study and corresponding doses]: There were no significant changes in appearance or behavior of male or female rats. Male rats in the 4.72 mg/m^3^ group showed a 20% reduction in body weight gain during the 12-week exposure period. No effects were detected in the examined hematological and serum clinical chemistry parameters. There were no observed differences in absolute or relative organ weights or morphological alterations in organs or tissues in any of the rats. From week 4 to week 12, erythrocyte AChE activity was reduced by 29–48% in male and 26–39% in female rats in the 4.72 mg/m^3^ group. Reductions in erythrocyte AChE activity in rats exposed to guthion doses <4.72 mg/m^3^ were 17% or less and are not considered an adverse effect. The investigator noted that brain AChE activity was not reduced at any of the concentrations tested, but no data were shown.

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a NOAEL of 1.24 mg/m^3^ and LOAEL of 4.72 mg/m^3^ for decreased erythrocyte AChE activity.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 3 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: The NOAEL of 1.24 mg/m^3^ was adjusted for intermittent exposure (NOAEL[ADJ]) as follows:

- NOAEL_[ADJ]_ = 1.24 mg/m^3^ x 6 hours/24 hours x 5 days/7 days
- NOAEL_[ADJ]_ = 0.22 mg/m^3^

The human equivalent concentration (HEC) of the NOAEL_[ADJ]_ was calculated using the equations below. The RDDR_[ER]_ is the regionally deposited dose ratio for the extrarespiratory effects. It is calculated using EPA’s software (version 2.3) for calculating RDDRs (EPA 1994b) and particle size and body weight data from Kimmerle (1976).

NOAEL_[HEC]_ = NOAEL_[ADJ]_ x RDDR_[ER]_

NOAEL_[HEC]_ = 0.22 mg/m^3^ x 1.695

NOAEL_[HEC]_ = 0.37 mg/m^3^

An RDDR_ER_ of 1.695 was estimated using the default parameters and body weight data presented in Table A-3.

Table A-3 Default Parameters Used in the Derivation of RDDR_ER_

Parameter | Humans | Rats
Body weight (kg) | 70.00 | 0.253^a^
Minute volume (L) | 13.80 | 0.182
ET area (cm^2^)^b^ | 200.00 | 15.00
TB area (cm^2^)^c^ | 3,200.00 | 22.50
PU area (m^2^)^d^ | 54.00 | 0.34

a 12-week body weight value from Kimmerle (1976)

b Extrathoracic respiratory tract region

c Tracheobronchial respiratory tract region

d Pulmonary respiratory tract region

RDDR_ER_ = regionally deposited dose ratio for the extrarespiratory effects

Based on the information provided by Kimmerle (1976), it was assumed that the sizes of the aerosol particles were log-normally distributed in a manner such that 1.5% of these were <0.5 μm and 1.5% were >1.5 μm. Based on these assumptions, a geometric mean and geometric standard deviation of 0.9 and 0.23 μm, respectively, were calculated. These values were used to calculate a MMAD of 0.88 μm using the recommended equation in Table H-2 of the guidance document Methods for Derivation of Inhalation Reference Concentrations and Application of Inhalation Dosimetry (EPA 1994b).

MMAD = CMAD e ( 3 [ ln variance ]^2^ )

No conversion is required for the geometric standard deviation and the geometric standard deviation of 0.23 was used. CMAD is the count median aerodynamic diameter (0.9 μm).

The NOAEL_[HEC]_ of 0.37 mg/m^3^ was divided by an uncertainty factor of 30 (3 for extrapolation from animals to humans using dosimetric adjustment and 10 for human variability), resulting in an intermediate-duration inhalation MRL of 0.01 mg/m^3^. Application of the benchmark dose methodology to the data from Kimmerle (1976) was considered, but the data were presented as means without standard errors or standard deviations. Without these measures, the benchmark dose methodology could not be applied.

[underlined: Was a conversion used from intermittent to continuous exposure]? Yes, animals were exposed 6 hours/day, 5 days/week.

NOAEL_[ADJ]_ = 1.24 mg/m^3^ x 6 hours/24 hours x 5 days/7 days

NOAEL_[ADJ]_ = 0.22 mg/m^3^

[underlined: Other additional studies or pertinent information that lend support to this MRL]: No studies were located that allowed the derivation of a chronic-duration inhalation MRL. However, the available acute- and intermediate-duration inhalation studies and the acute-, intermediate-, and chronic-duration oral exposure studies support adopting the intermediate-duration MRL for chronic-duration exposures. Erythrocyte AChE activity was reduced by 29–48% in male rats and 26–39% in female rats exposed to guthion aerosols at 4.72 mg/m^3^ for 4–12 weeks without evident biologically significant changes in activity within the observation period (Kimmerle 1976). Intermediate- and chronic-duration oral exposures to 0.69–0.78 mg/kg/day in dogs (Allen et al. 1990) and 0.75–0.96 mg/kg/day in rats (Schmidt and Chevalier 1984) demonstrated biologically significant reductions in erythrocyte AChE activity that did not increase in severity with increasing exposure duration for up to 2 years (Allen et al. 1990; Schmidt and Chevalier 1984). Thus, a chronic-duration inhalation MRL of 0.01 mg/^m^3 is adopted from the intermediate-duration inhalation MRL and supported by the intermediate- and chronic-duration oral exposure studies in dogs and rats, which suggest that there are no duration-dependent increases in the severity of the inhibition of erythrocyte AChE activity.

[underlined: Agency Contacts (Chemical Managers)]: Nickolette Roney, Selene Chou, Yee-Wan Stevens

## Guthion Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Guthion
CAS Numbers: | 86-50-0
Date: | June 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 11
Species: | Rats

[underlined: Minimal Risk Level]: 0.01 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Astroff AB, Young AD. 1998. The relationship between maternal and fetal effects following maternal organophosphate exposure during gestation in the rat. Toxicol Ind Health 14(6):869–889.

[underlined: Experimental design]: Pregnant Sprague-Dawley rats were administered guthion (87.7% a.i.) at 0.5, 1.0, or 2.0 mg/kg/day by gavage on gestation days 6–15 (Astroff and Young 1998). Erythrocyte AChE was determined on gestation days 16 and 20 and brain AChE activity was determined on day 20. Inseminated females were examined daily for clinical signs. Dam body weight was determined on gestation days 0, 6, 8, 10, 12, 15, and 20. Food consumption was also determined periodically. Two groups of dams were used to establish maternal plasma ChE and erythrocyte and brain AChE activities on gestation days 16 and 20. Gross pathological examination of dams was conducted. Several reproductive and developmental end points, including early or late resorptions, implantation losses, and fetal survival, growth, and malformations were evaluated.

[underlined: Effect noted in study and corresponding doses]: A >80% reduction in erythrocyte AChE activity was observed 24 hours after the last 2.0 mg/kg/day dose. A 40% reduction in brain AChE activity was also observed in dams in the 2.0 mg/kg/day group. Maternal plasma ChE activity in the 2.0 mg/kg/day group was approximately 30% lower than in controls on gestation day 16, but the effect was not statistically significant. On gestation day 20, maternal brain AChE activity remained 27% lower than control values, but erythrocyte AChE and plasma ChE activities were not significantly different from those of control animals. In spite of the magnitude of the AChE and ChE activity reductions, there were no adverse clinical signs observed in the treated dams. There were no statistically or biologically significant reductions in brain or erythrocyte AChE or plasma ChE activities in rats administered 0.5 or 1 mg/kg/day.

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a BMDL of 1.04 mg/kg/day for inhibition of erythrocyte AChE activity.

[]NOAEL []LOAEL [X] BMDL

In order to derive a point of departure to calculate an acute-duration oral MRL, a benchmark dose approach was applied to the changes in erythrocyte AChE activity observed in female rats exposed to guthion by gavage during gestation. Benchmark doses (BMDs) and the lower bound of the 95% confidence limits of the benchmark doses (BMDLs) were calculated using the EPA Benchmark Dose Software (BMDS version 1.3.2) as described below. The BMDs and BMDLs are estimates of the doses associated with a 20% change in erythrocyte AChE activity.

The simplest continuous variable model (a linear model) did not provide an adequate fit to the erythrocyte AChE activity data. Thus, four continuous variable models were fit to the erythrocyte AChE activity data presented in Table A-4. Results of the modeling are presented in Table A-5.

Table A-4 Erythrocyte Cholinesterase Activity in Female Rats Administered Guthion

Guthion dose (mg/kg/day) | Number of animals tested | Erythrocyte AChE activity (IU/mL) | Standard deviation | Percent inhibition
0 | 24 | 0.36 | 0.10 | –
0.5 | 19 | 0.32 | 0.06 | 11
1.0 | 27 | 0.32 | 0.09 | 11
2.0 | 26 | 0.07 | 0.03 | 81

Source: Astroff and Young 1998

Table A-5 Model Predictions for Changes in Erythrocyte Cholinesterase Activity in Female Rats

Model | Variance p-value^a^ | X^2^ test statistic for means | df | p-Value for the means^a^ | AIC | BMD (mg/kg/day) | BMDL (mg/kg/day)
Linear^b^ | <0.0001 | 29.9864 | 2 | <0.0001 | −369.520477 | – | –
Linear^c^ | 0.1257 | 34.808 | 2 | <0.0001 | −390.935378 | – | –
2-degree polynomial^d^ | 0.1257 | 5.50139 | 1 | 0.019 | −418.242024 | – | –
Power^c,e^ | 0.1257 | 3.42361 | 1 | 0.06427 | −420.319802 | 1.32753 | 1.03839
Hill^f^ | 0.1257 | 3.42499 | 0 | NA | −418.318425 | – | –

a Values <0.05 fail to meet conventional goodness-of-fit criteria.

b Constant variance assumed

c Best-fitting model

d The lowest degree polynomial providing an adequate fit is reported

e Restrict power >=1

f Restrict n>1

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; df = degree of freedom; NA = not available (BMD software could not generate a model output); p = p-value from the chi-squared test

An adequate fit to the data for changes in erythrocyte AChE activity (as assessed by chi-square residuals and log-likelihood ratio fit tests in the BMDS) was obtained only with the power model with nonconstant variance assumed. A limitation of this data set is the large difference in maternal erythrocyte AChE activity between the NOAEL and the next, higher dose; relative to controls, maternal erythrocyte AChE activity was 11% lower in the 1 mg/kg/day group and 81% lower in the 2 mg/kg/day group. Statistical tests indicated that variances were not constant across exposure groups. The power model with nonhomogeneous variance (i.e., variance as a power function of dose) provided an improved fit to the data as assessed with Akaike’s Information Criteria (AIC) (Table A-5). The BMD and BMDL predicted from the power model are 1.33 and 1.04 mg/kg/day, respectively (Table A-5 and Figure A-1).

Figure A-1 Model Predictions for Changes in Erythrocyte Cholinesterase Activity in Female Rats

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Pasquet et al. (1976) observed reductions in erythrocyte and brain AChE activity in rats after single oral doses of guthion at 2, 6, or 18 mg/kg. Plasma ChE activity was reduced by ≥20% at >2 mg/kg, while brain AChE activity was reduced by ≥20% at doses ≥2 mg/kg/day. The results of the BMD approach is supported by the observation that application of a NOAEL approach (NOAEL ÷ 100 [uncertainty factor] would result in an MRL equal to the BMDL ÷ 100 [uncertainty factor].

[underlined: Agency Contacts (Chemical Managers)]: Nickolette Roney, Selene Chou, Yee-Wan Stevens

## Guthion Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Guthion
CAS Numbers: | 86-50-0
Date: | June 2008
Profile Status: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 40
Species: | Dog

[underlined: Minimal Risk Level]: 0.003 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Allen TR, Janiak T, Frei T, et al. 1990. 52-Week oral toxicity (feeding) study with azinphosmethyl (E 1582) in the dog. Mobay Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41804801.

[underlined: Experimental design]: Technical-grade guthion (91.9% a.i.) was administered to beagle dogs (four dogs/sex/group) in the food at 5.0, 25.0, and 125.0 ppm for up to 52 weeks. The guthion concentrations are equivalent to 0.15, 0.69, and 3.8 mg/kg/day, respectively, in male dogs, and 0.16, 0.78, and 4.3 mg/kg/day, respectively, in female dogs (Allen et al. 1990). The observations made at ≤26 weeks were used to derive the intermediate-duration MRL. Daily observations for clinical signs were conducted; body weight was determined weekly and food consumption was monitored daily. Hearing and ophthalmoscopic evaluations were conducted after 13, 26, and 52 weeks; hematological, clinical chemistry, and urinary chemistry parameters were determined on weeks 4, 13, 26, and 52; plasma ChE and erythrocyte AChE activities were determined on weeks 4, 13, and 26.

[underlined: Effect noted in study and corresponding doses]: Reductions of ≥20% in erythrocyte AChE activity were observed after 4, 13, and 26 weeks in male and female dogs administered guthion in food for up to 52 weeks (Allen et al. 1990). Dose-related reductions in erythrocyte AChE activity were evident at the week 4 sampling time. Erythrocyte AChE activity was further reduced from week 4 to week 13 but remained relatively constant from week 13 to 26 (Allen et al. 1990). Statistically nonsignificant reductions in erythrocyte AChE activity during the 26-week period were ≤8% in males at 0.15 mg/kg/day and 11–21% in females at 0.16 mg/kg/day. Reductions in erythrocyte AChE activity were 22–40% in males at 0.69 mg/kg/day and 20–43% in females at 0.78 mg/kg/day. Reductions in erythrocyte AChE activity from weeks 4 to 26 were 66–88% in males (3.8 mg/kg/day) and 86–92% in females (4.3 mg/kg/day). The relatively constant levels of erythrocyte AChE activity from weeks 4 to 26 suggest that the effects of guthion on AChE activity occur early and remain relatively steady during exposure. Male and female dogs administered 3.8 and 4.3 mg/kg/day, respectively, suffered from an increased incidence of mucoid diarrhea and occasional emesis. The same signs but with a greater severity were observed in male dogs at 0.69 mg/kg/day. These signs were believed to be related to guthion treatment. Terminal body weights were reduced by 12–16% in male and female dogs administered 3.8 and 4.3 mg/kg/day, respectively, although there was no difference in food consumption among treated and control animals. There were no treatment-related hematological effects or changes in urinalysis parameters. Findings were negative in hearing and ophthalmoscopic tests on weeks 13 and 26 and there was no treatment-related increase in mortality in any dose group (Allen et al. 1990). Clinical chemistry tests showed that albumin and albumin/globulin values were significantly reduced in males by 13 and 20%, respectively, in the 3.8 mg/kg/day group.

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a BMDL of 0.29 mg/kg/day for inhibition of erythrocyte AChE activity in female dogs after 26 weeks.

[ ] NOAEL [ ] LOAEL [X] BMDL

In order to derive a point of departure to calculate an intermediate-duration oral MRL, a benchmark dose approach was applied to the changes in erythrocyte AChE activity observed in male and female dogs exposed to guthion in the diet for 26 weeks (Allen et al. 1990). It is recognized that the small number of animals per dose group (4 dogs/group) limits the characterization of variability in the response to guthion. Benchmark doses (BMDs) and the lower bound of the 95% confidence limits of the benchmark doses (BMDLs) were calculated using the EPA Benchmark Dose Software (BMDS version 1.3.2) as described below. The BMDs and BMDLs are estimates of the doses associated with a 20% change in erythrocyte AChE activity. The simplest continuous variable model (a linear model) was fit to the erythrocyte AChE activity data presented in Table A-6.

Table A-6 Erythrocyte Cholinesterase Activity (μmol/mL/minute) in Beagle Dogs Administered Guthion in the Diet for 26 Weeks (Four Dogs/Sex/Dose Group)

Dose (mg/kg/day) | Mean (standard deviation) | Percent reduction
Males
0 | 2.57 (0.29) | –
0.15 | 2.37 (0.83) | 8
0.69 | 1.75 (0.21) | 32
3.8 | 0.32 (0.13) | 88^a^
Females
0 | 3.27 (0.38) | –
0.16 | 2.57 (0.63) | 21
0.78 | 2.03 (0.53) | 37^a^
4.3 | 0.28 (0.11) | 91^a^

a Statistically significant reduction

Source: Allen et al. 1990

A nonhomogeneous variance linear model provided an adequate fit to the erythrocyte AChE activity data for female but not male dogs after 26–week and it was concluded that the male data at 26 weeks were not suitable for BMD modeling. For the 26-week data in female dogs, the best-fitting linear model predicted a BMD of 0.96 mg/kg/day and a BMDL of 0.93 mg/kg/day. However, this BMDL for a 20% reduction in erythrocyte AChE activity in dogs is higher than the observed LOAELs of 0.69 and 0.78 mg/kg/day in male and female dogs, respectively (Allen et al. 1990). At these LOAELs, reductions in erythrocyte AChE activity in the range of 32–37% were observed after 26 weeks. Thus, the linear model appears to underpredict the response of erythrocyte AChE activity to guthion in female dogs after 26 weeks. Reexamination of the data plots suggests that the experimental data at the high dose might be a high-leverage point, which exerts a high degree of influence on the model results. The plot of the erythrocyte AChE activity in female dogs after 26 weeks is presented in Figure A-2. Given that for the derivation of an MRL the most pertinent part of the dose-response curve is that which lies at the lower doses, the high-dose data point was removed from the dataset and the model fitting was conducted as described before. A nonhomogeneous variance linear model provided an adequate fit to the erythrocyte AChE activity data for females at week 26 when the high dose was removed from the data set. None of the other continuous models available in the BMD software provided an adequate fit to the data. Results of the BMD linear modeling of the low-dose region of the dose-response curve are presented in Table A-7 and a plot of the 26-week data in females with the high-dose excluded is presented in Figure A-3.

Table A-7 Model Predictions for Erythrocyte AChE Activity in Female Beagle Dogs Exposed to Guthion in the Diet for 26 Weeks

Model | Variance p-value^a^ | X^2^ test statistic for means | df | p-value for the means^a^ | AIC | BMD (mg/kg/day) | BMDL (mg/kg/day)
Linear^b,c,d^ (high dose excluded) | 0.43 | 2.47 | 1 | 0.12 | 3.12 | 0.44 | 0.29

a Values <0.05 fail to meet conventional goodness-of-fit criteria.

b Constant variance assumed

c Best-fitting model

d Restriction = nonpositive

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; df = degree of freedom; p = p value from the Chi-squared test

Figure A-2 Erythrocyte AChE Activity in Female Beagle Dogs Exposed to Guthion in the Diet for 26 Weeks^*^ * BMDs and BMDLs are associated with a 20% change from the controls, and are in units of mg/kg/day. (Complete Dataset)

Figure A-3 Erythrocyte AChE Activity in Female Beagle Dogs Exposed to Guthion in the Diet for 26 Weeks^*^ * BMDs and BMDLs indicated are associated with a change of 20% change from the control, and are in units of mg/kg/day (High-dose Group Excluded)

A BMDL of 0.29 mg/kg/day was obtained by analysis of the low-dose region of the dose-response curve for dogs exposed for 26 weeks.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Inhibition of erythrocyte AChE activity was the most sensitive end point in a study with male and female rats administered technical-grade guthion in the feed for 13 weeks (Sheets et al. 1997). Brain and erythrocyte AChE activities were significantly inhibited in rats administered ≥0.91 mg/kg/day. The results obtained using the BMD approach are supported by those obtained using the NOAEL approach.

[underlined: Agency Contacts (Chemical Managers)]: Nickolette Roney, Selene Chou, Yee-Wan Stevens

## Guthion Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Guthion
CAS Numbers: | 86-50-0
Date: | June 2008
Profile Statius: | Final Draft Post-Public Comment
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 63
Species: | Dog

[underlined: Minimal Risk Level]: 0.003 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Allen TR, Janiak T, Frei T, et al. 1990. 52-Week oral toxicity (feeding) study with azinphosmethyl (E 1582) in the dog. Mobay Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41804801.

[underlined: Experimental design]: Technical-grade guthion (91.9% a.i.) was administered to beagle dogs (four dogs/sex/group) in the food at 5.0, 25.0, 125.0 ppm for up to 52 weeks. The guthion concentrations are equivalent to 0.15, 0.69, and 3.8 mg/kg/day, respectively, in male dogs, and 0.16, 0.78, and 4.3 mg/kg/day, respectively, in female dogs (Allen et al. 1990). Daily observations for clinical signs were conducted; body weight was determined weekly and food consumption was monitored daily. Hearing and ophthalmoscopic evaluations were conducted after 13, 26, and 52 weeks; hematological, clinical chemistry, and urinary chemistry parameters were determined on weeks 4, 13, 26, and 52; plasma ChE and erythrocyte AChE activities were determined prior to treatment and on weeks 4, 13, 26, and 52; brain AChE activity was determined on week 52. Terminal body weight and organ weights were determined and macroscopic and histopathological evaluations of organs were conducted.

[underlined: Effect noted in study and corresponding doses]: Dose-related reductions in erythrocyte AChE activity were evident in male and female dogs on week 52. A statistically nonsignificant reduction of 15% in erythrocyte AChE activity was observed in females at 0.16 mg/kg/day on week 52, but there was no effect in males. On week 52, reductions in erythrocyte AChE activity in males at 0.69 and 3.8 mg/kg/day were 27 and 86%, respectively. Females in the 0.78 and 4.3 mg/kg/day groups showed 35 and 86% reductions, respectively, in erythrocyte AChE activity. Brain AChE activity on week 52 in the 3.8 and 4.3 mg/kg/day groups was reduced by 27 and 20% in males and females, respectively. Reductions in brain AChE activity were 1 and 10% in female and male dogs receiving administered 0.78 and 0.69 mg/kg/day, respectively. No effect on brain AChE activity was observed in males administered 0.15 mg/kg/day or females administered 0.16 mg/kg/day. Plasma ChE activity was reduced by 53% in males and females administered 3.8 and 4.3 mg/kg/day, respectively. No statistically significant reductions in plasma ChE activity were observed in male or female dogs administered ≤0.69 or ≤0.78 mg/kg/day, respectively. Terminal body weights were reduced by 12% in males in the 3.8 mg/kg/day group and by 16% in females in the 4.3 mg/kg/day group, although there was no difference in food consumption among treated and control animals. There were no treatment-related hematological effects or changes in urinalysis parameters. Findings were negative in hearing and ophthalmoscopic tests conducted at study termination and there was no treatment-related increase in mortality in any dose group. There were no changes in absolute or relative organ weights in females at the doses tested. Absolute and relative spleen weights in were reduced in males in a dose-related manner with significant reductions in relative spleen weight at ≥0.69 mg/kg/day; however, congestion of the spleen and increased absolute spleen weight were observed in 4/4 male dogs in the control group. A 7–17% decrease in albumin and albumin/globulin values were observed on week 52 in males in the 3.8 mg/kg/day group. A 39 and 15% increase in P450 activity was observed in male dogs at 3.8 mg/kg/day and in female dogs at 4.3 mg/kg/day, respectively. A 34 and 30% increase in N-demethylase activity was observed in male dogs at 3.8 and in female dogs at 4.3 mg/kg/day, respectively. Other effects were restricted to the high dose groups (Allen et al. 1990).

[underlined: Dose and end point used for MRL derivation]: The MRL is based on a BMDL of 0.30 mg/kg/day for inhibition of erythrocyte AChE activity in male dogs after 52 weeks.

[ ] NOAEL [ ] LOAEL [X] BMDL

In order to derive a point of departure to calculate a chronic-duration oral MRL a benchmark dose approach was applied to the changes in erythrocyte AChE activity observed in male and female dogs exposed to guthion in the diet for 52 weeks (Allen et al. 1990). It is recognized that the small number of animals per dose group (4 dogs/group) limits the characterization of variability in the response to guthion. Benchmark doses (BMDs) and the lower bound of the 95% confidence limits of the benchmark doses (BMDLs) were calculated using the EPA Benchmark Dose Software (BMDS version 1.3.2) as described below. The BMDs and BMDLs are estimates of the doses associated with a 20% change in erythrocyte AChE activity. The simplest continuous variable model (a linear model) was fit to the erythrocyte AChE activity data presented in Table A-8.

Table A-8 Erythrocyte Cholinesterase Activity (μmol/mL/minute) in Beagle Dogs Administered Guthion in the Diet for 52 Weeks (Four Dogs/Sex/Dose Group)

Dose (mg/kg/day) | Mean (standard deviation) | Percent reduction
Males
0 | 2.87 (0.36) | –
0.15 | 3.01 (0.84) | 0
0.69 | 2.10 (0.45) | 27
3.8 | 0.41 (0.15) | 86^a^
Females
0 | 3.36 (1.72) | –
0.16 | 2.87 (0.73) | 15
0.78 | 2.20 (0.5) | 35^a^
4.3 | 0.47 (0.16) | 86^a^

a Statistically significant reduction

Source: Allen et al. 1990

The linear model under the assumption of constant variance did not provide an adequate fit for either the male or female erythrocyte AChE activity data at 52 weeks; however, a nonhomogeneous variance linear model provided an adequate fit to the erythrocyte AChE activity data for males and females at week 52. Therefore, the linear model with the assumption of nonhomogenous variance was chosen for estimating the BMDs and BMDLs for the males and females at week 52. The selected model predicted a BMD in the range of 0.90–1.0 mg/kg/day and a BMDL in the range of 0.85–0.97 mg/kg/day. However, these BMDLs for a 20% reduction in erythrocyte AChE activity in dogs are higher than the observed LOAELs of 0.69 and 0.78 mg/kg/day in male and female dogs, respectively (Allen et al. 1990). At these LOAELs, reductions in erythrocyte AChE activity in the range of 27–35% were observed after 52 weeks. Thus, the linear model appears to underpredict the response of erythrocyte AChE activity to guthion in dogs after 52 weeks. Reexamination of the data plots suggests that the experimental data at the high dose might be a high-leverage point which exerts a high degree of influence on the model results. The plots of the erythrocyte AChE activity in male and female dogs after 52 weeks are presented in Figures A-4(A) and A-5(A), respectively. Given that for the derivation of an MRL the most pertinent part of the dose-response curve is that which lies at the lower doses the high-dose data point was removed from the dataset and the model fitting was conducted as described before. A linear model with an assumption of homogenous variance provided an adequate fit to the 52-week data with dogs when the high-dose data were removed. The other continuous models in the software were also applied to the data, but did not provide adequate fits. Results of the BMD linear modeling of the low-dose region of the dose-response curve are presented in Table A-9. Plots of the 52-week data in males and females with the high-dose excluded are presented in Figures A-4(B) and A-5(B), respectively.

Table A-9 Model Predictions for Erythrocyte AChE Activity in Beagle Dogs Exposed to Guthion in the Diet for 52 Weeks

Model | Variance p-value^a^ | X^2^ test statistic for means | df | p-value for the means^a^ | AIC | BMD (mg/kg/day) | BMDL (mg/kg/day)
Male
Linear^b,c^ (high dose dropped) | 0.20 | 0.85 | 1 | 0.36 | 0.66 | 0.48 | 0.30
Female
Linear^b,c^ (high dose dropped) | 0.55 | 1.5 | 1 | 0.23 | 14.5 | 0.50 | 0.32

a Values <0.05 fail to meet conventional goodness-of-fit criteria.

b Constant variance assumed

c Restriction = nonpositive

AIC = Akaike’s Information Criteria; BMD = benchmark dose; BMDL = lower confidence limit (95%) on the benchmark dose; df = degree of freedom; p = p value from the Chi-squared test

Figure A-4 Erythrocyte AChE Activity in Male Beagle Dogs Exposed to Guthion in the Diet for 52 Weeks^*^ * BMDs and BMDLs are associated with a 20% change from the controls, and are in units of mg/kg/day.

Figure A-5 Erythrocyte AChE Activity in Female Beagle Dogs Exposed to Guthion in the Diet for 52 Weeks^*^ * BMDs and BMDLs are associated with a 20% change from controls, and are in units of mg/kg/day.

BMDLs of in the range of 0.30–0.32 mg/kg/day were obtained by analysis of the low-dose region only of the dose-response curve for dogs exposed for 52 weeks. The lowest BMDL (0.30 mg/kg/day) was selected as the point of departure. Applying an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) to the BMDL yields a chronic-duration oral MRL of 0.003 mg/kg/day.

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Inhibition of erythrocyte AChE activity also was the most sensitive effect in a 2-year study with rats administered guthion in the diet at 0.25–2.3 mg/kg/day in males and 0.31–3.11 mg/kg/day in females (Schmidt and Chevalier 1984). These studies support selection of the effect on erythrocyte AChE activity as the critical end point for chronic oral exposure to azinphos-methyl. The 52-week study in dogs (Allen et al. 1990) was selected to derive the chronic-duration oral MRL because, at similar doses (0.69–0.78 mg/kg/day in dogs after 52 weeks and 0.75–0.96 mg/kg/day in rats after 2 years), there was a more marked reduction in erythrocyte AChE in dogs (20–43%) than in rats (10–22%).

[underlined: Agency Contacts (Chemical Managers)]: Nickolette Roney, Selene Chou, Yee-Wan Stevens