# CONTRIBUTORS & REVIEWERS

- Hana R. Pohl, M.D., Ph.D. (Lead)
- Melanie Buser, M.P.H.
- Breanna Alman, M.P.H.
- Selene Chou, Ph.D.
- Mike Fay, Ph.D.
- Carolyn Harper, Ph.D.
- Susan Zells Ingber, A.B., M.S.P.P.
- Jennifer Przybyla, Ph.D.
- Jane Li, Ph.D.
- Angela Ragin-Wilson, Ph.D.
- Henry Abadin, M.S.P.H.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA

- David W. Wohlers, Ph.D.
- Mario Citra, Ph.D.
- Christina Coley, B.S.
- Lisa Ingerman, Ph.D., D.A.B.T.
- SRC, Inc., North Syracuse, NY

- Kaley Beins, M.P.H.
- Lauren Brown, M.S., D.A.B.T.
- Paulina Do, M.P.H.
- Adriana Antezana, M.P.H.
- Hannah Derrick, B.S.
- Kerry Diskin, Ph.D.
- Andrea Chiger, M.P.H.
- Abt Associates, Rockville, MD
- Chimeddulam Dalaijamts, PhD
- Texas A&M University (under subcontract to Abt Associates)

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice. EPA.

## PEER REVIEWERS

1. Annaclaire De Roos Ph.D., M.P.H., Associate Professor, Environmental and Occupational Health, Dornsrife School of Public Health, Drexel University, Philadelphia, Pennsylvania
2. David A. Eastmond, Ph.D., Professor and Toxicologist, Department of Molecular Cell and Systems Biology, University of California, Riverside, Riverside, California
3. Renata Marino Romano, Ph.D., Professora Adjunta, Departamento de Farmácia, Universidade Estadual do Centro-Oeste – UNICENTRO, Guarapuava, Brazil

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Peer reviewers for subsequent revision to Section 2.19 (Cancer) and Appendix A (MRL Worksheets) in the Toxicological Profile for Glyphosate were:

1. James V. Bruckner, Ph.D., Professor of Pharmacology & Toxicology, Department of Pharmaceutical & Biomedical Sciences, College of Pharmacy, University of Georgia
2. David A. Eastmond, Ph.D., Professor and Toxicologist, Department of Molecular Cell and Systems Biology, University of California, Riverside, Riverside, California
3. Paul J. Mills, Ph.D., Professor of Family Medicine and Public Health, University of California, San Diego
4. Renata Marino Romano, Ph.D., Professora Adjunta, Departamento de Farmácia, Universidade Estadual do Centro-Oeste – UNICENTRO, Guarapuava, Brazil

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.