# VERSION HISTORY

Date | Description
August 2020 | Final toxicological profile released
April 2019 | Draft for public comment toxicological profile released