# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Glyphosate is an organic acid composed of a phosphonomethyl and glycine component. The chemical name for glyphosate is N-(phosphonomethyl) glycine. Glyphosate is a zwitterion with four distinct dissociation constants (pKa values are depicted below) and exists as different ionic species depending on the pH of its surroundings. Glyphosate is an amphoteric chemical and may react as an acid or a base under certain conditions.

Chemical structure of Glyphosate

Glyphosate isopropylamine (Chemical Abstracts Registry Number [CASRN] 38641-94-0) is one of the salt forms of glyphosate used in commercial herbicides employing glyphosate as an active ingredient. This substance is registered as a pesticide by the EPA (1993) and is used to control broadleaf weeds and grasses; in food and nonfood settings, flower gardens, lawns, turf, residential areas, and forests; and along roadsides. Use of glyphosate as a pesticide outside of an agricultural context would be considered non-agricultural. Some labels may list the active ingredient in a formulation of glyphosate and the acid equivalents (AE), which is the theoretical yield of the parent acid from the formulated ester or salt. For example, the AE of glyphosate isopropylamine salts is 74%.

Detailed information on the chemical identity of glyphosate and glyphosate isopropylamine is provided in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Detailed information on the physical and chemical properties of glyphosate and glyphosate isopropylammonium is provided in Table 4-2.

Table 4-1 Chemical Identity of Glyphosate and Glyphosate Isopropylamine^a^

Characteristic | Information
Chemical name | Glyphosate | Glyphosate isopropylamine
Synonym(s) | Glyphosphate; N-(phosphonomethyl) glycine; phosphonomethyliminoacetic acid; glyphosate acid | Glycine, N-(phosphonomethyl)-, compound with 2-propanamine (1:1); glyphosate-isopropylammonium; glyphosate mono(isopropylamine) salt; glyphosate-mono(isopropylammonium); N-(phosphonomethyl)glycine, isopropylamine salt
Partial list of registered trade name(s) | Pondmaster; Roundup® Max; Glifoglex; Glycel; Muster; Rondo; Sonic; Spasor; Sting; Tumbleweed; MON-0573; CP 67573 | Roundup®; Rondo; Rodeo; Glifonox; Glycel; MON-0139; CP 70139; Shackle^b^
Chemical formula | C_3_H_8_NO_5_P | C_3_H_8_NO_5_P.C_3_H_9_N
Chemical structure
CAS Registry Number | 1071-83-6 | 38641-94-0

a All information obtained from McBean (2011), O’Neil et al. (2013), and/or ChemIDplus (2017) unless noted otherwise.

b EPA 1993.

CAS = Chemical Abstracts Service

Table 4-2 Physical and Chemical Properties of Glyphosate and its Isopropylamine Salt^a^

Property | Glyphosate | Glyphosate isopropylamine salt
Molecular weight | 169.1 | 228.2
Color | White | White
Physical state | Solid; crystals | Powder
Melting point | 230°C (decomposes) | Two stages: 143–164 and 189–223°C
Boiling point | No data | Decomposes without boiling
Density at 20°C | 1.705 | 1.482
Odor | Odorless | Odorless
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water at 25°C | 12,000 mg/L; 10,500 mg/L (pH 1.9, 20°C) | 1,050,000 mg/L (pH 4.3, 25°C)
Organic solvent(s) | Insoluble in most organic solvents: acetone, ethanol, and xylene | Dichloromethane 184 mg/L at 20°C; methanol 15,880 mg/L at 20°C
Dissociation constants: | pKa_1_ 0.8; pKa_2_ 3_;_ pKa_3_ 6; pKa_4_ 11; pKa_1_^b^ <2; pKa_2_^b^ 2.6; pKa_3_^b^ 5.6; pKa_4_^b^ 10.6 | pKa_1_ 2.18 at 20°C (monophosphate); pKa_2_ 5.77 at 20°C (carboxylic acid)
Partition coefficients:
Log K_ow_ | <−3.4 | −5.4
Log K_oc_ | 3.4–3.7 (K_oc_=2,600–4,900)^c^; −2.8–3.1 (K_oc_=0.00169–2,080 L/kg)^d^ | 3.3 (K_oc_ = 2,080 L/kg)^d^
Vapor pressure at 25°C | 9.8×10^−8^ mmHg | 1.58×10^−8^ mmHg
Henry’s law constant | 2.1×10^−12^ atm-m^3^/mol at 25°C^e^ | 3.3×10^−15^ atm-m^3^/mol at 25°C^e^
Autoignition temperature | No data | No data
Flashpoint | Not flammable | No data
Flammability limits | No data | No data
Explosive limits | No data | No data

a All information obtained from either McBean (2011) or O’Neil et al. (2013).

b Sprankle et al. 1975.

c Glass 1987.

d Predicted values from EPA CompTox Chemicals Dashboard

e EPI Suite 2012.