# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR GLYPHOSATE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to glyphosate.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for glyphosate. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of glyphosate have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of glyphosate are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The following main databases were searched in February 2015 and September 2017:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, and Medical Subject Headings (MeSH) terms for glyphosate. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to glyphosate were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations. The reference sections of the gray literature were used as quality assurance (QA) to ensure that no studies were missed during the literature review process. The ToxProfiles rely on peer reviewed data such as published studies and reports from government agencies or international organizations. In certain cases (e.g. ATSDR’s use of EPA’s DERs), ATSDR will rely on peer reviewed studies and reports evaluating unpublished data or original studies that are not available to ATSDR.

Table B-2 Database Query Strings Pre-Public Comment Searches

Database search date | Query string
PubMed; 9/2017 | (“glyphosate”[nm] OR “1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw] OR “Roundup”[tw] OR “34494-03-6”[tw] OR “MON 0459”[tw] OR “40465-66-5”[tw] OR “MON 14420”[tw] OR “MON 8750”[tw] OR “Roundup Hi-Load”[tw] OR “Roundup PRODry”[tw] OR “70393-85-0”[tw] OR “MON 8000”[tw] OR “Monsanto 8000”[tw] OR “Polado”[tw] OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate”[tw] OR “39600-42-5”[tw] OR “Glyphosate potassium”[tw] OR “Glyphosate monopotassium salt”[tw] OR “Glyphosate potassium”[tw] OR “Glyphosate-potassium”[tw] OR “Monopotassium glyphosate”[tw] OR “Roundup Attack”[tw] OR “Roundup Energy”[tw] OR “Roundup Maxload”[tw] OR “Roundup Original Max”[tw] OR “Roundup Power Max”[tw] OR “Roundup Ultramax II”[tw] OR “Roundup Weathermax”[tw] OR “Touchdown Forte HiTech”[tw] OR “Transorb R”[tw] OR “Weathermax”[tw] OR “Zapp Qi”[tw] OR “70901-12-1”[tw] OR “Glyphosate-potassium”[tw] OR “Potassium glyphosate”[tw] OR “Potassium N-(phosphonomethyl)glycine”[tw] OR “Uragan Forte”[tw] OR “VisionMAX”[tw] OR “N-(phosphonomethyl)glycine potassium salt”[tw] OR “114370-14-8”[tw] OR “Glyphosate ammonium”[tw] OR “N-(phosphonomethyl)glycine ammonium salt”[tw] OR “69254-40-6”[tw] OR “Glyphosate-diammonium”[tw] OR “Diammonium N-(phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)glycine diammonium salt”[tw]) AND (cancer[sb] OR “neoplasms”[mh] OR “carcinogenicity tests”[mh] OR “carcinogens”[mh] OR “cell division/drug effects”[mh] OR “cell cycle/drug effects”[mh] OR “cell line, tumor/drug effects”[mh] OR “gene expression regulation, neoplastic”[mh] OR “neoplasm proteins/drug effects”[mh] OR “angiogenesis inducing agents”[mh] OR “myelodysplastic-myeloproliferative diseases”[mh] OR cancer*[tw] OR carcinog*[tw] OR carcinom*[tw] OR cocarcinog*[tw] OR lymphoma*[tw] OR neoplas*[tw] OR oncogen*[tw] OR precancer*[tw] OR tumor*[tw] OR tumour*[tw]) AND (2014/02/01 : 3000[dp] OR 2015/02/01 : 3000[mhda] OR 2015/02/01 : 3000[crdat] OR 2015/02/01 : 3000[edat]); (“glyphosate, isopropyl amine salt”[nm] OR “N-(phosphonomethyl)glycine trimethylsulfonium salt”[nm] OR “38641-94-0”[tw] OR “Glyphosate-isopropylammonium”[tw] OR “Glyphosate isopropylamine salt”[tw] OR “Azural AT”[tw] OR “CP 70139”[tw] OR “Fosulen”[tw] OR “Glifosato estrella”[tw] OR “Glycel”[tw] OR “Glycine, N-(phosphonomethyl)-, cmpd with 2-propanamine (1:1)”[tw] OR “Glyfos AU”[tw] OR “Glyfos BIO”[tw] OR “Glyphosate isopropylamine salt”[tw] OR “Glyphosate mono(isopropylamine) salt”[tw] OR “Glyphosate-isopropylammonium”[tw] OR “Glyphosate-mono(isopropylammonium)”[tw] OR “Landmaster”[tw] OR “MON 139”[tw] OR “MON 39”[tw] OR “N-(Phosphonomethyl)glycine isopropylamine salt”[tw] OR “N-(Phosphonomethyl)glycine isopropylammonium salt”[tw] OR “N-(Phosphonomethyl)glycine monoisopropylamine salt”[tw] OR “Nitosorg”[tw] OR “Ron-do”[tw] OR “Utal”[tw] OR “Utal (herbicide)”[tw] OR “Vision (herbicide)”[tw] OR “2-Propanamine, compd, with N-(phosphonomethyl)glycine (1:1)”[tw] OR “Glycine, N-(phosphonomethyl)-, compd. with 2-propanamine (1:1)”[tw] OR “N-(Phosphonomethyl)glycine, compound with 2-propylamine (1:1)”[tw] OR “Isopropylamine glyphosate”[tw] OR “81591-81-3”[tw] OR “Glyphosate-trimesium”[tw] OR “Glyphosphate-trimesium”[tw] OR “Avans 330”[tw] OR “Glyphosate mono(trimethylsulfonium) salt”[tw] OR “Glyphosate trimethylsulfonium salt”[tw] OR “Glyphosate-trimesium”[tw] OR “Medallon”[tw] OR “Ouragan”[tw] OR “R 50224”[tw] OR “SC 0224”[tw] OR “Sulfosate”[tw] OR “Sulphosate”[tw] OR “Touchdown herbicide”[tw] OR “Trimethylsulfonium carboxymethylamino-methylphosphonate”[tw] OR “Trimethylsulfonium glyphosate”[tw] OR “Glycine, N-(phosphonomethyl)-, ion(1-), trimethylsulfonium”[tw] OR “Sulfosate”[tw]) AND (cancer[sb] OR “neoplasms”[mh] OR “carcinogenicity tests”[mh] OR “carcinogens”[mh] OR “cell division/drug effects”[mh] OR “cell cycle/drug effects”[mh] OR “cell line, tumor/drug effects”[mh] OR “gene expression regulation, neoplastic”[mh] OR “neoplasm proteins/drug effects”[mh] OR “angiogenesis inducing agents”[mh] OR “myelodysplastic-myeloproliferative diseases”[mh] OR cancer*[tw] OR carcinog*[tw] OR carcinom*[tw] OR cocarcinog*[tw] OR lymphoma*[tw] OR neoplas*[tw] OR oncogen*[tw] OR precancer*[tw] OR tumor*[tw] OR tumour*[tw]) AND (2014/02/01 : 3000[dp] OR 2015/02/01 : 3000[mhda] OR 2015/02/01 : 3000[crdat] OR 2015/02/01 : 3000[edat])
2/2015 | (“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb]); (“Roundup”[tw] AND (monsanto[tw] OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[MeSH Terms] OR “antifungal”[tw] OR “anti-fungal”[tw] OR “enzyme inhibitors”[Pharmacological Action] OR “enzyme inhibitors”[MeSH Terms] OR (“enzyme”[tw] AND inhibitor*[tw]) OR “enzyme inhibitors”[tw] OR “enzyme inhibitor”[tw] OR “herbicides”[Pharmacological Action] OR “herbicides”[MeSH Terms] OR “herbicides”[tw] OR “herbicide”[tw] OR “uncoupling agents”[Pharmacological Action] OR “uncoupling agents”[MeSH Terms] OR (“uncoupling”[tw] AND agent*[tw]) OR “uncoupling agent”[tw] OR “uncoupling agents”[tw] OR “pesticides”[mh] OR pesticide*[tw])) NOT ((“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb])); (“34494-03-6”[tw] OR “MON 0459”[tw] OR “40465-66-5”[tw] OR “MON 14420”[tw] OR “MON 8750”[tw] OR “Roundup Hi-Load”[tw] OR “Roundup PRODry”[tw] OR “70393-85-0”[tw] OR “MON 8000”[tw] OR “Monsanto 8000”[tw] OR “Polado”[tw] OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr]); (“39600-42-5”[tw] OR “Glyphosate potassium”[tw] OR “Glyphosate monopotassium salt”[tw] OR “Glyphosate potassium”[tw] OR “Glyphosate-potassium”[tw] OR “Monopotassium glyphosate”[tw] OR “Roundup Attack”[tw] OR “Roundup Energy”[tw] OR “Roundup Maxload”[tw] OR “Roundup Original Max”[tw] OR “Roundup Power Max”[tw] OR “Roundup Ultramax II”[tw] OR “Roundup Weathermax”[tw] OR “Touchdown Forte HiTech”[tw] OR “Transorb R”[tw] OR “Weathermax”[tw] OR “Zapp Qi”[tw] OR “70901-12-1”[tw] OR “Glyphosate-potassium”[tw] OR “Potassium glyphosate”[tw] OR “Potassium N-(phosphonomethyl)glycine”[tw] OR “Uragan Forte”[tw] OR “VisionMAX”[tw] OR “N-(phosphonomethyl)glycine potassium salt”[tw] OR “114370-14-8”[tw] OR “Glyphosate ammonium”[tw] OR “N-(phosphonomethyl)glycine ammonium salt”[tw] OR “69254-40-6”[tw] OR “Glyphosate-diammonium”[tw] OR “Diammonium N-(phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)glycine diammonium salt”[tw]) NOT ((“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb]) OR (“Roundup”[tw] AND (monsanto[tw] OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[MeSH Terms] OR “antifungal”[tw] OR “anti-fungal”[tw] OR “enzyme inhibitors”[Pharmacological Action] OR “enzyme inhibitors”[MeSH Terms] OR (“enzyme”[tw] AND inhibitor*[tw]) OR “enzyme inhibitors”[tw] OR “enzyme inhibitor”[tw] OR “herbicides”[Pharmacological Action] OR “herbicides”[MeSH Terms] OR “herbicides”[tw] OR “herbicide”[tw] OR “uncoupling agents”[Pharmacological Action] OR “uncoupling agents”[MeSH Terms] OR (“uncoupling”[tw] AND agent*[tw]) OR “uncoupling agent”[tw] OR “uncoupling agents”[tw] OR “pesticides”[mh] OR pesticide*[tw]))); (((“glyphosate, isopropyl amine salt”[nm]) OR (“N-(phosphonomethyl)glycine trimethylsulfonium salt”[nm])) NOT ((“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb]) OR (“Roundup”[tw] AND (monsanto[tw] OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[MeSH Terms] OR “antifungal”[tw] OR “anti-fungal”[tw] OR “enzyme inhibitors”[Pharmacological Action] OR “enzyme inhibitors”[MeSH Terms] OR (“enzyme”[tw] AND inhibitor*[tw]) OR “enzyme inhibitors”[tw] OR “enzyme inhibitor”[tw] OR “herbicides”[Pharmacological Action] OR “herbicides”[MeSH Terms] OR “herbicides”[tw] OR “herbicide”[tw] OR “uncoupling agents”[Pharmacological Action] OR “uncoupling agents”[MeSH Terms] OR (“uncoupling”[tw] AND agent*[tw]) OR “uncoupling agent”[tw] OR “uncoupling agents”[tw] OR “pesticides”[mh] OR pesticide*[tw])))) OR ((“38641-94-0”[tw] OR “Glyphosate-isopropylammonium”[tw] OR “Glyphosate isopropylamine salt”[tw] OR “Azural AT”[tw] OR “CP 70139”[tw] OR “Fosulen”[tw] OR “Glifosato estrella”[tw] OR “Glycel”[tw] OR “Glycine, N-(phosphonomethyl)-, cmpd with 2-propanamine (1:1)”[tw] OR “Glyfos AU”[tw] OR “Glyfos BIO”[tw] OR “Glyphosate isopropylamine salt”[tw] OR “Glyphosate mono(isopropylamine) salt”[tw] OR “Glyphosate-isopropylammonium”[tw] OR “Glyphosate-mono(isopropylammonium)”[tw] OR “Landmaster”[tw] OR “MON 139”[tw] OR “MON 39”[tw] OR “N-(Phosphonomethyl)glycine isopropylamine salt”[tw] OR “N-(Phosphonomethyl)glycine isopropylammonium salt”[tw] OR “N-(Phosphonomethyl)glycine monoisopropylamine salt”[tw] OR “Nitosorg”[tw] OR “Ron-do”[tw] OR “Utal”[tw] OR “Utal (herbicide)”[tw] OR “Vision (herbicide)”[tw] OR “2-Propanamine, compd, with N-(phosphonomethyl)glycine (1:1)”[tw] OR “Glycine, N-(phosphonomethyl)-, compd. with 2-propanamine (1:1)”[tw] OR “N-(Phosphonomethyl)glycine, compound with 2-propylamine (1:1)”[tw] OR “Isopropylamine glyphosate”[tw] OR “81591-81-3”[tw] OR “Glyphosate-trimesium”[tw] OR “Glyphosphate-trimesium”[tw] OR “Avans 330”[tw] OR “Glyphosate mono(trimethylsulfonium) salt”[tw] OR “Glyphosate trimethylsulfonium salt”[tw] OR “Glyphosate-trimesium”[tw] OR “Medallon”[tw] OR “Ouragan”[tw] OR “R 50224”[tw] OR “SC 0224”[tw] OR “Sulfosate”[tw] OR “Sulphosate”[tw] OR “Touchdown herbicide”[tw] OR “Trimethylsulfonium carboxymethylamino-methylphosphonate”[tw] OR “Trimethylsulfonium glyphosate”[tw] OR “Glycine, N-(phosphonomethyl)-, ion(1-), trimethylsulfonium”[tw] OR “Sulfosate”[tw]) NOT ((“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb]) OR (“Roundup”[tw] AND (monsanto[tw] OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[MeSH Terms] OR “antifungal”[tw] OR “anti-fungal”[tw] OR “enzyme inhibitors”[Pharmacological Action] OR “enzyme inhibitors”[MeSH Terms] OR (“enzyme”[tw] AND inhibitor*[tw]) OR “enzyme inhibitors”[tw] OR “enzyme inhibitor”[tw] OR “herbicides”[Pharmacological Action] OR “herbicides”[MeSH Terms] OR “herbicides”[tw] OR “herbicide”[tw] OR “uncoupling agents”[Pharmacological Action] OR “uncoupling agents”[MeSH Terms] OR (“uncoupling”[tw] AND agent*[tw]) OR “uncoupling agent”[tw] OR “uncoupling agents”[tw] OR “pesticides”[mh] OR pesticide*[tw]))))
Toxline; 9/2017 | ( “lancer herbicide” OR “mon 2139” OR “mon 3539” OR “mon 6000” OR “phorsat” OR “phosphonomethyliminoacetic acid” OR “rebel garden” OR “roundup max” OR “safal” OR “scout herbicide” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “ ( carboxymethylamino ) methylphosphonic acid” OR “carboxymethylaminomethanephosphinic acid” OR “c k yuyos fav” OR “cp 67573” OR “folusen” OR “forsat” OR “glialka” OR “glifosan 747” OR “glygran” OR “glyphodin a” OR “glyphomax” OR “ground bio” OR “herbatop” OR “hm 2028” OR “kickdown” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “glifoglex” OR “gliphosate” OR “gliz” OR “glyfos” OR “glyphosate” OR “glyphosphate” OR “n ( phosphonomethyl ) glycine” OR “n ( phosphonomethyl ) glycine” OR “n phosphomethylglycine” OR “n phosphonomethylglycine” OR “phosphonomethylglycine” OR “pondmaster” OR “silglif” OR “yerbimat” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; 1071-83-6 [rn] AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org] ( #7 NOT #4 ) AND NOT PubMed [org] AND NOT pubdart [org]; “roundup” AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) [not] PubMed [org] [not] pubdart [org]; ( “mon 0459” OR “40465 66 5” OR “mon 14420” OR “mon 8750” OR “roundup hi load” OR “roundup prodry” OR “mon 8000” OR “monsanto 8000” OR “polado” OR “trisodium hydrogen bis ( n ( phosphonatomethyl ) aminoacetate ) ” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( 34494-03-6 [rn] OR 70393-85-0 [rn] ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “glyphosate diammonium” OR “diammonium n ( phosphonomethyl ) glycine” OR “n ( phosphonomethyl ) glycine diammonium salt” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “roundup weathermax” OR “touchdown forte hitech” OR “transorb r” OR “weathermax” OR “zapp qi” OR “glyphosate potassium” OR “potassium glyphosate” OR “potassium n ( phosphonomethyl ) glycine” OR “uragan forte” OR “visionmax” OR “n ( phosphonomethyl ) glycine potassium salt” OR “glyphosate ammonium” OR “n ( phosphonomethyl ) glycine ammonium salt” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “glyphosate potassium” OR “glyphosate monopotassium salt” OR “glyphosate potassium” OR “glyphosate potassium” OR “monopotassium glyphosate” OR “roundup attack” OR “roundup energy” OR “roundup maxload” OR “roundup original max” OR “roundup power max” OR “roundup ultramax ii” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( 39600-42-5 [rn] OR 39600-55-0 [rn] OR 39600-56-1 [rn] OR 39600-58-3 [rn] OR 40465-59-6 [rn] OR 40465-64-3 [rn] OR 40465-67-6 [rn] OR 40465-70-1 [rn] OR 40465-90-5 [rn] OR 40465-91-6 [rn] OR 70901-12-1 [rn] OR 114370-14-8 [rn] OR 69254-40-6 [rn] ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “sulphosate” OR “touchdown herbicide” OR “trimethylsulfonium carboxymethylamino methylphosphonate” OR “trimethylsulfonium glyphosate” OR “glycine n ( phosphonomethyl) ion ( 1 ) trimethylsulfonium” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “isopropylamine glyphosate” OR “glyphosate trimesium” OR “glyphosphate trimesium” OR “avans 330” OR “glyphosate mono ( trimethylsulfonium ) salt” OR “glyphosate trimethylsulfonium salt” OR “glyphosate trimesium” OR “medallon” OR “ouragan” OR “r 50224” OR “sc 0224” OR “sulfosate” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “n ( phosphonomethyl ) glycine monoisopropylamine salt” OR “nitosorg” OR “utal” OR “utal ( herbicide ) ” OR “vision ( herbicide ) ” OR “2 propanamine compd with n ( phosphonomethyl ) glycine ( 1 1 ) ” OR “glycine n ( phosphonomethyl ) compd with 2 propanamine ( 1 1 ) ” OR “n ( phosphonomethyl ) glycine compound with 2 propylamine ( 1 1 ) ” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “glyphosate mono ( isopropylamine ) salt” OR “glyphosate isopropylammonium” OR “glyphosate mono ( isopropylammonium ) ” OR “landmaster” OR “mon 139” OR “mon 39” OR “n ( phosphonomethyl ) glycine isopropylamine salt” OR “n ( phosphonomethyl ) glycine isopropylammonium salt” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “glyphosate isopropylammonium” OR “glyphosate isopropylamine salt” OR “azural at” OR “cp 70139” OR “fosulen” OR “glifosato estrella” OR “glycel” OR “glycine n ( phosphonomethyl ) cmpd with 2 propanamine ( 1 1 ) ” OR “glyfos au” OR “glyfos bio” OR “glyphosate isopropylamine salt” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( 38641-94-0 [rn] OR 81591-81-3 [rn] ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
2/2015 | “Glifoglex” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “Glyphosate” OR “Glyphosphate” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phosphonomethylglycine” OR “Pondmaster” OR “Silglif” OR “yerbimat”; “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifosan 747” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown”; “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “Phorsat” OR “Phosphonomethyliminoacetic acid” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide”; “roundup”; 34494-03-6[rn] OR 70393-85-0[rn]; “MON 0459” OR “40465-66-5” OR “MON 14420” OR “MON 8750” OR “Roundup Hi-Load” OR “Roundup PRODry” OR “MON 8000” OR “Monsanto 8000” OR “Polado” OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate)”; 39600-42-5[rn] OR 39600-55-0[rn] OR 39600-56-1[rn] OR 39600-58-3[rn] OR 40465-59-6[rn] OR 40465-64-3[rn] OR 40465-67-6[rn] OR 40465-70-1[rn] OR 40465-90-5[rn] OR 40465-91-6[rn] OR 70901-12-1[rn] OR 114370-14-8[rn] OR 69254-40-6[rn]; “Glyphosate potassium” OR “Glyphosate monopotassium salt” OR “Glyphosate potassium” OR “Glyphosate-potassium” OR “Monopotassium glyphosate” OR “Roundup Attack” OR “Roundup Energy” OR “Roundup Maxload” OR “Roundup Original Max” OR “Roundup Power Max” OR “Roundup Ultramax II”; “Roundup Weathermax” OR “Touchdown Forte HiTech” OR “Transorb R” OR “Weathermax” OR “Zapp Qi” OR “Glyphosate-potassium” OR “Potassium glyphosate” OR “Potassium N-(phosphonomethyl)glycine” OR “Uragan Forte” OR “VisionMAX” OR “N-(phosphonomethyl)glycine potassium salt” OR “Glyphosate ammonium” OR “N-(phosphonomethyl)glycine ammonium salt”; “Glyphosate-diammonium” OR “Diammonium N-(phosphonomethyl)glycine” OR “N-(phosphonomethyl)glycine diammonium salt”; 38641-94-0[rn] OR 81591-81-3[rn]; “Glyphosate-isopropylammonium” OR “Glyphosate isopropylamine salt” OR “Azural AT” OR “CP 70139” OR “Fosulen” OR “Glifosato estrella” OR “Glycel” OR “Glycine, N-(phosphonomethyl)-, cmpd with 2-propanamine (1:1)” OR “Glyfos AU” OR “Glyfos BIO” OR “Glyphosate isopropylamine salt”; “Glyphosate mono(isopropylamine) salt” OR “Glyphosate-isopropylammonium” OR “Glyphosate-mono(isopropylammonium)” OR “Landmaster” OR “MON 139” OR “MON 39” OR “N-(Phosphonomethyl)glycine isopropylamine salt” OR “N-(Phosphonomethyl)glycine isopropylammonium salt”; “N-(Phosphonomethyl)glycine monoisopropylamine salt” OR “Nitosorg” OR “Utal” OR “Utal (herbicide)” OR “Vision (herbicide)” OR “2-Propanamine, compd, with N-(phosphonomethyl)glycine (1:1)” OR “Glycine, N-(phosphonomethyl)-, compd. with 2-propanamine (1:1)” OR “N-(Phosphonomethyl)glycine, compound with 2-propylamine (1:1)”; “Isopropylamine glyphosate” OR “Glyphosate-trimesium” OR “Glyphosphate-trimesium” OR “Avans 330” OR “Glyphosate mono(trimethylsulfonium) salt” OR “Glyphosate trimethylsulfonium salt” OR “Glyphosate-trimesium” OR “Medallon” OR “Ouragan” OR “R 50224” OR “SC 0224” OR “Sulfosate”; “Sulphosate” OR “Touchdown herbicide” OR “Trimethylsulfonium carboxymethylamino-methylphosphonate” OR “Trimethylsulfonium glyphosate” OR “Glycine, N- N-phosphonemethyl)-, ion(1-), trimethylsulfonium”
Toxcenter; 9/2017 | L1 9995 SEA 1071-83-6; L2 92 SEA 34494-03-6 OR 40465-66-5 OR 70393-85-0; L3 80 SEA 39600-42-5 OR 39600-55-0 OR 39600-56-1 OR 39600-58-3 OR 40465-59-6 OR 40465-64-3 OR 40465-67-6 OR 40465-70-1 OR 40465-90-5 OR 40465-91-6; L4 101 SEA 70901-12-1 OR 114370-14-8 OR 69254-40-6; L5 2022 SEA 38641-94-0 OR 81591-81-3; L6 10037 SEA L1 OR L2 OR L3 OR L4; L7 6132 SEA L6 NOT (TSCATS/FS OR PATENT/DT); L8 2048 SEA L6 AND (PY>2013 OR ED>=20150201); L9 1260 SEA L7 AND (PY>2013 OR ED>=20150201); L10 751 SEA L5 NOT L6; L11 530 SEA L10 NOT (TSCATS/FS OR PATENT/DT); L12 63 SEA L11 AND (PY>2013 OR ED>=20150201); L13 56 SEA L9 AND (CANCER? OR CARCINOG? OR CARCINOM? OR COCARCINOG? OR LYMPHOMA? OR NEOPLAS? OR ONCOGEN? OR PRECANCER? OR TUMOR? OR TUMOUR?); L14 6 SEA L12 AND (CANCER? OR CARCINOG? OR CARCINOM? OR COCARCINOG? OR LYMPHOMA? OR NEOPLAS? OR ONCOGEN? OR PRECANCER? OR TUMOR? OR TUMOUR?); L15 16 SEA L13 AND MEDLINE/FS; L16 40 SEA L13 NOT L15; L17 44 DUP REM L15 L16 (12 DUPLICATES REMOVED); ANSWERS ‘1-44’ FROM FILE TOXCENTER; L*** DEL 16 S L13 AND MEDLINE/FS; L*** DEL 16 S L13 AND MEDLINE/FS; L18 16 SEA L17; L*** DEL 40 S L13 NOT L15; L*** DEL 40 S L13 NOT L15; L19 28 SEA L17; L20 28 SEA (L18 OR L19) NOT MEDLINE/FS; D SCAN L20; L21 401072 SEA 14 NOT MEDLINE/FS; L22 6 SEA L14 NOT MEDLINE/FS; L23 6 DUP REM L22 (0 DUPLICATES REMOVED); ANSWERS ‘1-6’ FROM FILE TOXCENTER; D SCAN L23; FILE ‘MEDLINE’ ENTERED AT 19:10:42 ON 14 SEP 2017; CHARGED TO COST=EH011.10.01; L24 QUE ACROCHORDON OR ACROCHORDONS OR ADENOMATOSIS OR ADENOMATOUS OR ADENOSIS OR AMYLOIDOSES OR AMYLOIDOSIS OR ANAPLASIA OR ANGIOENDOTHELIOMATOSIS OR ANGIOMATOSIS OR BUSCHKE-LOWENSTEIN OR CANCER OR CANCEROUS OR CANCERS OR CARCINOGEN; L25 QUE CARCINOGENESIS OR CARCINOGENIC OR CARCINOGENICITY OR CARCINOGENS OR CARCINOID OR CARCINOMATOSIS OR CHERUBISM OR CIN OR CLL OR COCARCINOGENESIS OR DERMOID OR DYSMYELOPOIESIS OR ENCHONDROMATOSIS OR EPIDERMOID OR ERYTHROLEUKAEMIA OR ERYTHROLE UKAEMIAS; L26 QUE ERYTHROLEUKEMIA OR ERYTHROLEUKEMIAS OR ERYTHROPLAKIA OR ERYTHROPLAKIAS OR ERYTHROPLASIA OR ESSENTIAL-THROMBOCYTHEMIA OR EXOSTOSIS OR FIBROADENOSIS OR FIBROID OR FIBROIDS OR FIBROMATOSIS OR GLIOMATOSIS OR GLOMANGIOMATOSIS OR GRANULOMATOS IS; L27 QUE GYNAECOMASTIA OR GYNECOMASTIA OR HEMANGIOMATOSIS OR HODGKIN OR HODGKINS OR LEIOMYOMATOSIS OR LEUKAEMIA OR LEUKAEMIA S OR LEUKEMIA OR LEUKEMIAS OR LEUKOPLAKIA OR LEUKOPLAKIAS OR LEUKOSTASIS OR LIPOBLASTOMATOSIS OR LIPOMATOSIS; L28 QUE LYMPHANGIOLEIOMYOMATOSIS OR LYMPHANGIOMATOSIS OR LYMPHANGIO MYOMATOSIS OR LYMPHOPROLIFERATION OR LYMPHOPROLIFERATIONS OR LYMPHOPROLIFERATIVE OR LYMPHOSCINTIGRAPHIC OR LYMPHOSCINTIGRAPH Y OR MACROGLOBULINEMIA OR MACROGLOBULINEMIAS; L29 QUE MALIGNANCIES OR MALIGNANCY OR MALIGNANT OR MASTOCYTOSIS OR MEIGS-SYNDROME OR MELANOMATOSIS OR MENINGIOMATOSIS OR METAPLASI A OR MICROMETASTASES OR MICROMETASTASIS OR MYCOSIS-FUNGOIDES OR MYELODYSPLASIA OR MYELODYSPLASIAS; L30 QUE MYELODYSPLASTIC OR MYELOFIBROSIS OR MYELOMATOSIS OR MYELOPROLIFERATION OR MYELOPROLIFERATIONS OR MYELOPROLIFERATIVE OR MYELOSUPPRESSION OR MYOFIBROMATOSIS OR NEOPLASIA OR NEOPLASM OR NEOPLASMS OR NEOPLASTIC OR NEURILEMMOMATOSIS; L31 QUE NEUROFIBROMATOSIS OR NEURONEVUS OR NONHODGKIN OR NONHODGKIN S OR NONSEMINOMATOUS OR NSCLC OR ONCOGENE-FUSION OR OPSOCLONUS-MYOCLONUS OR PAPILLOMATA OR PAPILLOMATOSIS OR PARANEOPLASTIC OR PEUTZ-JEGHERS OR POLYPOSIS OR PRECANCER; L32 QUE PRECANCEROUS OR SARCOMATOSIS OR SCHWANNOMATOSIS OR SEMINOMATOUS OR SEZARY-SYNDROME OR STRUMA-OVARII OR TUMOR OR TUMORGENESIS OR TUMORGENIC OR TUMORIGENESIS OR TUMORIGENIC OR TUMOR-MARKER OR TUMOR-MARKERS OR TUMOROGENESIS; L33 QUE TUMOROGENIC OR TUMORS OR TUMOUR OR TUMOURS OR WALDENSTROM OR WALDENSTROMS OR “5Q-SYNDROME” OR “WAGR SYNDROME” OR (ASCO NOT FUNGI) OR (SENTINEL-LYMPH-NODE NOT BIOPSY); L34 QUE L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33; DIS COST; FILE ‘TOXCENTER’ ENTERED AT 19:12:52 ON 14 SEP 2017; CHARGED TO COST=EH011.10.01; L47 1 SEA L9 AND ?IOMA; DIS COST; L48 26 SEA L9 AND (?AOMA OR ?BOMA OR ?COMA OR ?DOMA OR ?EOMA OR ?FOMA OR ?GOMA OR ?HOMA OR ?IOMA OR ?JOMA OR ?KOMA OR ?LOMA OR ?MOMA OR ?NOMA OR ?OOMA OR ?POMA OR ?QOMA OR ?ROMA OR ?SOMA OR ?TOMA OR ?UOMA OR ?VOMA OR ?WOMA); L49 0 SEA L9 AND (?XOMA OR ?YOMA OR ?ZOMA OR ?AOMAS OR ?BOMAS OR ?COMAS OR ?DOMAS OR ?EOMAS OR ?FOMAS OR ?GOMAS OR ?HOMAS OR ?IOMAS OR ?JOMAS OR ?KOMAS OR ?LOMAS OR ?MOMAS OR ?NOMAS OR ?OOMAS OR ?POMAS OR ?QOMAS OR ?ROMAS); L50 0 SEA L9 AND (?SOMAS OR ?TOMAS OR ?UOMAS OR ?VOMAS OR ?WOMAS OR ?XOMAS OR ?YOMAS OR ?ZOMAS); L51 48 SEA L9 AND L34; L52 68 SEA L48 OR L49 OR L50 OR L51; L53 16 SEA L52 NOT L13; L54 20 SEA L52 AND MEDLINE/FS; L55 7 SEA L53 AND MEDLINE/FS; L56 12 DUP REM L53 (4 DUPLICATES REMOVED); ANSWERS ‘1-12’ FROM FILE TOXCENTER; D SCAN L56; L57 6 SEA L12 AND L34; L58 2 SEA L12 AND (?AOMA OR ?BOMA OR ?COMA OR ?DOMA OR ?EOMA OR ?FOMA OR ?GOMA OR ?HOMA OR ?IOMA OR ?JOMA OR ?KOMA OR ?LOMA OR ?MOMA OR ?NOMA OR ?OOMA OR ?POMA OR ?QOMA OR ?ROMA OR ?SOMA OR ?TOMA OR ?UOMA OR ?VOMA OR ?WOMA); L59 0 SEA L12 AND (?XOMA OR ?YOMA OR ?ZOMA OR ?AOMAS OR ?BOMAS OR ?COMAS OR ?DOMAS OR ?EOMAS OR ?FOMAS OR ?GOMAS OR ?HOMAS OR ?IOMAS OR ?JOMAS OR ?KOMAS OR ?LOMAS OR ?MOMAS OR ?NOMAS OR ?OOMAS OR ?POMAS OR ?QOMAS OR ?ROMAS); L60 0 SEA L12 AND (?SOMAS OR ?TOMAS OR ?UOMAS OR ?VOMAS OR ?WOMAS OR ?XOMAS OR ?YOMAS OR ?ZOMAS); L61 8 SEA L57 OR L58; L62 8 SEA L61 NOT (L13 OR L52); L63 7 DUP REM L62 (1 DUPLICATE REMOVED); ANSWERS ‘1-7’ FROM FILE TOXCENTER; D SCAN L63
2/2017 | FILE ‘TOXCENTER’ ENTERED AT 19:21:56 ON 18 FEB 2015; CHARGED TO COST=EH011.05.01.01; L1 8342 SEA 1071-83-6; L2 63 SEA 34494-03-6 OR 40465-66-5 OR 70393-85-0; L3 8 SEA L2 NOT L1; L4 53 SEA 39600-42-5 OR 39600-55-0 OR 39600-56-1 OR 39600-58-3 OR 40465-59-6 OR 40465-64-3 OR 40465-67-6 OR 40465-70-1 OR 40465-90-5 OR 40465-91-6; L5 59 SEA 70901-12-1 OR 114370-14-8 OR 69254-40-6; L6 1828 SEA 38641-94-0 OR 81591-81-3; L7 8369 SEA L1 OR L2 OR L4 OR L5; L8 5041 SEA L7 NOT (PATENT/DT OR TSCATS/FS); ACT TOXQUERY/Q; ---------; L9 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L10 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L11 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L12 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L13 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L14 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L15 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L16 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L17 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L18 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L19 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L20 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L21 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L22 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L23 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L24 QUE (ENDOCRIN? AND DISRUPT?); L25 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L26 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L27 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L28 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L29 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L30 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L31 QUE (NEPHROTOX? OR HEPATOTOX?); L32 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L33 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L34 QUE L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33; L35 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L36 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L37 QUE L34 OR L35 OR L36; L38 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L39 QUE L37 OR L38; ---------; L40 2675 SEA L8 AND L37; L41 525 SEA L40 AND MEDLINE/FS; L42 833 SEA L40 AND BIOSIS/FS; L43 1263 SEA L40 AND CAPLUS/FS; L44 0 SEA L40 AND IPA/FS; L45 54 SEA L40 NOT (L41 OR L42 OR L43); L46 2064 DUP REM L41 L42 L43 L45 (611 DUPLICATES REMOVED); ANSWERS ‘1-2064’ FROM FILE TOXCENTER; L*** DEL 525 S L40 AND MEDLINE/FS; L*** DEL 525 S L40 AND MEDLINE/FS; L47 525 SEA L46; L*** DEL 833 S L40 AND BIOSIS/FS; L*** DEL 833 S L40 AND BIOSIS/FS; L48 644 SEA L46; L*** DEL 1263 S L40 AND CAPLUS/FS; L*** DEL 1263 S L40 AND CAPLUS/FS; L49 859 SEA L46; L*** DEL 54 S L40 NOT (L41 OR L42 OR L43); L*** DEL 54 S L40 NOT (L41 OR L42 OR L43); L50 36 SEA L46; L51 1539 SEA (L47 OR L48 OR L49 OR L50) NOT MEDLINE/FS; L52 1532 SEA L51 AND L1; L53 7 SEA L51 NOT L52; D SCAN L53; L54 688 SEA L6 NOT L7; L55 485 SEA L54 NOT (PATENT/DT OR TSCATS/FS); L56 314 SEA L55 AND L37; L57 0 SEA L56 AND MEDLINE/FS; L58 85 SEA L56 AND BIOSIS/FS; L59 218 SEA L56 AND CAPLUS/FS; L60 1 SEA L56 AND IPA/FS; L61 274 DUP REM L56 (40 DUPLICATES REMOVED); ANSWERS ‘1-274’ FROM FILE TOXCENTER; D SCAN L52

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
9/2017; 2/2015 | Compounds searched: 1071-83-6; 34494-03-6; 40465-66-5; 70393-85-0; 38641-94-0; 81591-81-3
NTP
9/2017 | glyphosate AND cancer; Limited to 2010-2017
2/2015 | “1071-83-6” OR “Glifoglex” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “Glyphosate” OR “Glyphosphate” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phosphonomethylglycine” OR “Pondmaster” OR “Silglif” OR “yerbimat”; “34494-03-6” OR “40465-66-5” OR “70393-85-0” OR “MON 0459” OR “MON 14420” OR “MON 8750” OR “Roundup Hi-Load” OR “Roundup PRODry” OR “MON 8000” OR “Monsanto 8000” OR “Polado” OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate)”; “38641-94-0” OR “Glyphosate-isopropylammonium” OR “Glyphosate isopropylamine salt” OR “Azural AT” OR “Buggy” OR “CP 70139” OR “Fosulen” OR “Glifosato estrella” OR “Glycel” OR “Glyfos AU” OR “Glyfos BIO” OR “Glyphosate isopropylamine salt” OR “Glyphosate mono(isopropylamine) salt” OR “Glyphosate-isopropylammonium” OR “Glyphosate-mono(isopropylammonium)” OR “Landmaster” OR “MON 139” OR “MON 39” OR “N-(Phosphonomethyl)glycine isopropylamine salt” OR “N-(Phosphonomethyl)glycine isopropylammonium salt” OR “N-(Phosphonomethyl)glycine monoisopropylamine salt” OR “Nitosorg” OR “Ron-do” OR “Utal” OR “Vision (herbicide)” OR “Roundup” OR “Isopropylamine glyphosate” OR “81591-81-3” OR “Glyphosate-trimesium” OR “Glyphosphate-trimesium” OR “Avans 330” OR “Glyphosate mono(trimethylsulfonium) salt” OR “Glyphosate trimethylsulfonium salt” OR “Glyphosate-trimesium” OR “Medallon” OR “Ouragan” OR “R 50224” OR “SC 0224” OR “Sulfosate” OR “Sulphosate” OR “Touchdown” OR “Trimethylsulfonium carboxymethylamino-methylphosphonate” OR “Trimethylsulfonium glyphosate”
NPIRS | PC Codes searched: 417300; 103603; 103613; 103604; 103607; 103601; 128501
9/2017; 2/2015
NIH RePORTER
4/2017 | Text Search: “Carboxymethylamino)methylphosphonic acid” OR “2-Propanamine, compd, with N-(phosphonomethyl)glycine (1:1)” OR “Avans 330” OR “Azural AT” OR “C-K Yuyos FAV” OR “Carboxymethylaminomethanephosphinic acid” OR “CP 67573” OR “CP 70139” OR “Diammonium N-(phosphonomethyl)glycine” OR “Folusen” OR “Forsat” OR “Fosulen” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “Glifosato estrella” OR “gliphosate” OR “Gliz” OR “Glycel” OR “Glycine, N-(phosphonomethyl)-, cmpd with 2-propanamine (1:1)” OR “Glycine, N-(phosphonomethyl)-, compd. with 2-propanamine (1:1)” OR “Glycine, N-(phosphonomethyl)-, ion(1-), trimethylsulfonium” OR “Glyfos” OR “Glyfos AU” OR “Glyfos BIO” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “Landmaster” OR “Medallon” OR “MON 0459” OR “MON 139” OR “MON 14420” OR “MON 2139” OR “MON 3539” OR “MON 39” OR “MON 6000” OR “MON 8000” OR “MON 8750” OR “Monsanto 8000” OR “N-(phosphonomethyl)-Glycine” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)glycine ammonium salt” OR “N-(phosphonomethyl)glycine diammonium salt” OR “N-(Phosphonomethyl)glycine isopropylamine salt” OR “N-(Phosphonomethyl)glycine isopropylammonium salt” OR “N-(Phosphonomethyl)glycine monoisopropylamine salt” OR “N-(phosphonomethyl)glycine potassium salt” OR “N-(Phosphonomethyl)glycine, compound with 2-propylamine (1:1)” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Nitosorg” OR “Ouragan” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Polado” OR “Pondmaster” OR “Potassium N-(phosphonomethyl)glycine” OR “R 50224” OR “Rebel Garden” OR “Ron-do” OR “Roundup” OR “Safal” OR “SC 0224” OR “Scout herbicide” OR “Silglif” OR “Sulfosate” OR “Sulphosate” OR “Touchdown Forte HiTech” OR “Touchdown herbicide” OR “Transorb R” OR “Trimethylsulfonium carboxymethylamino-methylphosphonate” OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate” OR “Uragan Forte” OR “Utal” OR “Vision herbicide” OR “VisionMAX” OR “Weathermax” OR “yerbimat” OR “Zapp Qi” (Advanced), Search in: Projects AdminIC: All, Fiscal Year: Active Projects, 2017, 2016, 2015, 2014, 2013, 2012
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2015 and 2017 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 5,592
- Number of records identified from other strategies: 211
- Total number of records to undergo literature screening: 5,803

Following the publication of the draft profile and receipt of public comments, ATSDR conducted an updated literature review to capture any references published after the conclusion of the original literature review. The updated literature review searches occurred in September and October 2019 using the following sources:

- Toxline
- IPA
- Science Direct
- PubMed
- BIOSIS
- MEDLINE
- SciFinder

In each database, searches were limited to references published from 2017 (i.e., the year the literature searches for glyphosate were last conducted) to the present date. Table B-4 includes the search strings used in each of these searches.

Table B-4 Database Query Strings Post-Public Comment Searches

Database search date | Query String
Toxline; 9/2019 | ( “lancer herbicide” OR “mon 2139” OR “mon 3539” OR “mon 6000” OR “phorsat” OR “phosphonomethyliminoacetic acid” OR “rebel garden” OR “roundup max” OR “safal” OR “scout herbicide” )
Toxline; 9/2019 | ( “ ( carboxymethylamino ) methylphosphonic acid” OR “carboxymethylaminomethanephosphinic acid” OR “c k yuyos fav” OR “cp 67573” OR “folusen” OR “forsat” OR “glialka” OR “glifosan 747” OR “glygran” OR “glyphodin a” OR “glyphomax” OR “ground bio” OR “herbatop” OR “hm 2028” OR “kickdown” )
Toxline; 9/2019 | ( “glifoglex” OR “gliphosate” OR “gliz” OR “glyfos” OR “glyphosate” OR “glyphosphate” OR “n ( phosphonomethyl ) glycine” OR “n ( phosphonomethyl ) glycine” OR “n phosphomethylglycine” OR “n phosphonomethylglycine” OR “phosphonomethylglycine” OR “pondmaster” OR “silglif” OR “yerbimat” )
Toxline; 9/2019 | 1071-83-6 [rn]
Toxline; 9/2019 | “roundup”
Toxline; 9/2019 | ( “mon 0459” OR “40465 66 5” OR “mon 14420” OR “mon 8750” OR “roundup hi load” OR “roundup prodry” OR “mon 8000” OR “monsanto 8000” OR “polado” OR “trisodium hydrogen bis ( n ( phosphonatomethyl ) aminoacetate ) ” )
Toxline; 9/2019 | ( 34494-03-6 [rn] OR 70393-85-0 [rn] )
Toxline; 9/2019 | ( “glyphosate diammonium” OR “diammonium n ( phosphonomethyl ) glycine” OR “n ( phosphonomethyl ) glycine diammonium salt” )
Toxline; 9/2019 | (roundup weathermax OR touchdown forte hitech OR transorb r OR weathermax OR zapp qi OR glyphosate potassium OR potassium glyphosate OR potassium n ( phosphonomethyl ) glycine OR uragan forte OR visionmax OR n ( phosphonomethyl ) glycine potassium salt OR glyphosate ammonium OR n ( phosphonomethyl ) glycine ammonium salt)
Toxline; 9/2019 | ( “glyphosate potassium” OR “glyphosate monopotassium salt” OR “glyphosate potassium” OR “glyphosate potassium” OR “monopotassium glyphosate” OR “roundup attack” OR “roundup energy” OR “roundup maxload” OR “roundup original max” OR “roundup power max” OR “roundup ultramax ii” )
Toxline; 9/2019 | (39600-42-5 [rn] OR 39600-55-0 [rn] OR 39600-56-1 [rn] OR 39600-58-3 [rn] OR 40465-59-6 [rn] OR 40465-64-3 [rn] OR 40465-67-6 [rn] OR 40465-70-1 [rn] OR 40465-90-5 [rn] OR 40465-91-6 [rn] OR 70901-12-1 [rn] OR 114370-14-8 [rn] OR 69254-40-6 [rn])
IPA; 9/2019 | (“1071-83-6” or “38641-94-0”).rn. and (“Glyphosate” or “glyphosate isopropylamine” or “Glyphosphate” or “N-(phosphonomethyl)glycine ” or “glycine, N-(phosphonomethyl)-, compound with 2-propanamine (1:1)” or “phosphonomethyliminoacetic acid” or “glyphosate acid” or “glyphosate-isopropylammonium” or “glyphosate mono(isopropylamine) salt” or “glyphosate-mono(isopropylammonium)” or “N-(phosphonomethyl)glycine, isopropylamine salt” or “Pondmaster” or “Roundup Max” or “Glifoglex” or “Glycel” or “Rondo” or “Spasor” or “Tumbleweed” or “MON-0573” or “CP 67573” or “Roundup” or “Glifonox” or “MON-0139” or “CP 70139”).rw. and (“Glyphosate” or “glyphosate isopropylamine”).sh.
Science Direct; 9/2019 | Glyphosate OR Glyphosphate OR “N phosphonomethyl glycine” OR “phosphonomethyliminoacetic acid” OR “glyphosate acid”
Science Direct; 9/2019 | “Glyphosate isopropylamine” OR “Glycine, N-phosphonomethyl-, compound with 2-propanamine 1:1” OR “glyphosate-isopropylammonium” OR “glyphosate monoisopropylamine salt” OR “glyphosate-monoisopropylammonium” OR “N phosphonomethyl)glycine, isopropylamine salt”
Science Direct; 9/2019 | “Pondmaster” OR “Roundup Max” OR Glifoglex OR Glycel OR Rondo OR Spasor OR Tumbleweed OR “MON-0573” OR “CP 67573”
Science Direct; 9/2019 | Roundup OR Rondo OR Glifonox OR Glycel OR “MON-0139” OR “CP 70139”
Science Direct; 9/2019 | (Sonic AND Herbicide NOT Ultrasonic) OR (Rodeo and Herbicide)
PubMed; 9/2019 | (“glyphosate”[nm] OR “1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw] OR “Roundup”[tw] OR “34494-03-6”[tw] OR “MON 0459”[tw] OR “40465-66-5”[tw] OR “MON 14420”[tw] OR “MON 8750”[tw] OR “Roundup Hi-Load”[tw] OR “Roundup PRODry”[tw] OR “70393-85-0”[tw] OR “MON 8000”[tw] OR “Monsanto 8000”[tw] OR “Polado”[tw] OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate”[tw] OR “39600-42-5”[tw] OR “Glyphosate potassium”[tw] OR “Glyphosate monopotassium salt”[tw] OR “Glyphosate potassium”[tw] OR “Glyphosate-potassium”[tw] OR “Monopotassium glyphosate”[tw] OR “Roundup Attack”[tw] OR “Roundup Energy”[tw] OR “Roundup Maxload”[tw] OR “Roundup Original Max”[tw] OR “Roundup Power Max”[tw] OR “Roundup Ultramax II”[tw] OR “Roundup Weathermax”[tw] OR “Touchdown Forte HiTech”[tw] OR “Transorb R”[tw] OR “Weathermax”[tw] OR “Zapp Qi”[tw] OR “70901-12-1”[tw] OR “Glyphosate-potassium”[tw] OR “Potassium glyphosate”[tw] OR “Potassium N-(phosphonomethyl)glycine”[tw] OR “Uragan Forte”[tw] OR “VisionMAX”[tw] OR “N-(phosphonomethyl)glycine potassium salt”[tw] OR “114370-14-8”[tw] OR “Glyphosate ammonium”[tw] OR “N-(phosphonomethyl)glycine ammonium salt”[tw] OR “69254-40-6”[tw] OR “Glyphosate-diammonium”[tw] OR “Diammonium N-(phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)glycine diammonium salt”[tw]) AND (cancer[sb] OR “neoplasms”[mh] OR “carcinogenicity tests”[mh] OR “carcinogens”[mh] OR “cell division/drug effects”[mh] OR “cell cycle/drug effects”[mh] OR “cell line, tumor/drug effects”[mh] OR “gene expression regulation, neoplastic”[mh] OR “neoplasm proteins/drug effects”[mh] OR “angiogenesis inducing agents”[mh] OR “myelodysplastic-myeloproliferative diseases”[mh] OR cancer*[tw] OR carcinog*[tw] OR carcinom*[tw] OR cocarcinog*[tw] OR lymphoma*[tw] OR neoplas*[tw] OR oncogen*[tw] OR precancer*[tw] OR tumor*[tw] OR tumour*[tw]) AND (2017/01/01 : 3000[dp])
PubMed; 9/2019 | (“glyphosate, isopropyl amine salt”[nm] OR “N-(phosphonomethyl)glycine trimethylsulfonium salt”[nm] OR “38641-94-0”[tw] OR “Glyphosate-isopropylammonium”[tw] OR “Glyphosate isopropylamine salt”[tw] OR “Azural AT”[tw] OR “CP 70139”[tw] OR “Fosulen”[tw] OR “Glifosato estrella”[tw] OR “Glycel”[tw] OR “Glycine, N-(phosphonomethyl)-, cmpd with 2-propanamine (1:1)”[tw] OR “Glyfos AU”[tw] OR “Glyfos BIO”[tw] OR “Glyphosate isopropylamine salt”[tw] OR “Glyphosate mono(isopropylamine) salt”[tw] OR “Glyphosate-isopropylammonium”[tw] OR “Glyphosate-mono(isopropylammonium)”[tw] OR “Landmaster”[tw] OR “MON 139”[tw] OR “MON 39”[tw] OR “N-(Phosphonomethyl)glycine isopropylamine salt”[tw] OR “N-(Phosphonomethyl)glycine isopropylammonium salt”[tw] OR “N-(Phosphonomethyl)glycine monoisopropylamine salt”[tw] OR “Nitosorg”[tw] OR “Ron-do”[tw] OR “Utal”[tw] OR “Utal (herbicide)”[tw] OR “Vision (herbicide)”[tw] OR “2-Propanamine, compd, with N-(phosphonomethyl)glycine (1:1)”[tw] OR “Glycine, N-(phosphonomethyl)-, compd. with 2-propanamine (1:1)”[tw] OR “N-(Phosphonomethyl)glycine, compound with 2-propylamine (1:1)”[tw] OR “Isopropylamine glyphosate”[tw] OR “81591-81-3”[tw] OR “Glyphosate-trimesium”[tw] OR “Glyphosphate-trimesium”[tw] OR “Avans 330”[tw] OR “Glyphosate mono(trimethylsulfonium) salt”[tw] OR “Glyphosate trimethylsulfonium salt”[tw] OR “Glyphosate-trimesium”[tw] OR “Medallon”[tw] OR “Ouragan”[tw] OR “R 50224”[tw] OR “SC 0224”[tw] OR “Sulfosate”[tw] OR “Sulphosate”[tw] OR “Touchdown herbicide”[tw] OR “Trimethylsulfonium carboxymethylamino-methylphosphonate”[tw] OR “Trimethylsulfonium glyphosate”[tw] OR “Glycine, N-(phosphonomethyl)-, ion(1-), trimethylsulfonium”[tw] OR “Sulfosate”[tw]) AND (cancer[sb] OR “neoplasms”[mh] OR “carcinogenicity tests”[mh] OR “carcinogens”[mh] OR “cell division/drug effects”[mh] OR “cell cycle/drug effects”[mh] OR “cell line, tumor/drug effects”[mh] OR “gene expression regulation, neoplastic”[mh] OR “neoplasm proteins/drug effects”[mh] OR “angiogenesis inducing agents”[mh] OR “myelodysplastic-myeloproliferative diseases”[mh] OR cancer*[tw] OR carcinog*[tw] OR carcinom*[tw] OR cocarcinog*[tw] OR lymphoma*[tw] OR neoplas*[tw] OR oncogen*[tw] OR precancer*[tw] OR tumor*[tw] OR tumour*[tw]) AND (2017/01/01 : 3000[dp])
PubMed; 9/2019 | (“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb]) AND (2017/01/01 : 3000[dp])
PubMed; 9/2019 | (“Roundup”[tw] AND (monsanto[tw] OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[MeSH Terms] OR “antifungal”[tw] OR “anti-fungal”[tw] OR “enzyme inhibitors”[Pharmacological Action] OR “enzyme inhibitors”[MeSH Terms] OR (“enzyme”[tw] AND inhibitor*[tw]) OR “enzyme inhibitors”[tw] OR “enzyme inhibitor”[tw] OR “herbicides”[Pharmacological Action] OR “herbicides”[MeSH Terms] OR “herbicides”[tw] OR “herbicide”[tw] OR “uncoupling agents”[Pharmacological Action] OR “uncoupling agents”[MeSH Terms] OR (“uncoupling”[tw] AND agent*[tw]) OR “uncoupling agent”[tw] OR “uncoupling agents”[tw] OR “pesticides”[mh] OR pesticide*[tw])) NOT ((“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb])) AND (2017/01/01 : 3000[dp])
PubMed; 9/2019 | (“34494-03-6”[tw] OR “MON 0459”[tw] OR “40465-66-5”[tw] OR “MON 14420”[tw] OR “MON 8750”[tw] OR “Roundup Hi-Load”[tw] OR “Roundup PRODry”[tw] OR “70393-85-0”[tw] OR “MON 8000”[tw] OR “Monsanto 8000”[tw] OR “Polado”[tw] OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr]) AND (2017/01/01 : 3000[dp])
PubMed; 9/2019 | (“39600-42-5”[tw] OR “Glyphosate potassium”[tw] OR “Glyphosate monopotassium salt”[tw] OR “Glyphosate potassium”[tw] OR “Glyphosate-potassium”[tw] OR “Monopotassium glyphosate”[tw] OR “Roundup Attack”[tw] OR “Roundup Energy”[tw] OR “Roundup Maxload”[tw] OR “Roundup Original Max”[tw] OR “Roundup Power Max”[tw] OR “Roundup Ultramax II”[tw] OR “Roundup Weathermax”[tw] OR “Touchdown Forte HiTech”[tw] OR “Transorb R”[tw] OR “Weathermax”[tw] OR “Zapp Qi”[tw] OR “70901-12-1”[tw] OR “Glyphosate-potassium”[tw] OR “Potassium glyphosate”[tw] OR “Potassium N-(phosphonomethyl)glycine”[tw] OR “Uragan Forte”[tw] OR “VisionMAX”[tw] OR “N-(phosphonomethyl)glycine potassium salt”[tw] OR “114370-14-8”[tw] OR “Glyphosate ammonium”[tw] OR “N-(phosphonomethyl)glycine ammonium salt”[tw] OR “69254-40-6”[tw] OR “Glyphosate-diammonium”[tw] OR “Diammonium N-(phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)glycine diammonium salt”[tw]) NOT ((“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb]) OR (“Roundup”[tw] AND (monsanto[tw] OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[MeSH Terms] OR “antifungal”[tw] OR “anti-fungal”[tw] OR “enzyme inhibitors”[Pharmacological Action] OR “enzyme inhibitors”[MeSH Terms] OR (“enzyme”[tw] AND inhibitor*[tw]) OR “enzyme inhibitors”[tw] OR “enzyme inhibitor”[tw] OR “herbicides”[Pharmacological Action] OR “herbicides”[MeSH Terms] OR “herbicides”[tw] OR “herbicide”[tw] OR “uncoupling agents”[Pharmacological Action] OR “uncoupling agents”[MeSH Terms] OR (“uncoupling”[tw] AND agent*[tw]) OR “uncoupling agent”[tw] OR “uncoupling agents”[tw] OR “pesticides”[mh] OR pesticide*[tw]))) AND (2017/01/01 : 3000[dp])
PubMed; 9/2019 | (((“glyphosate, isopropyl amine salt”[nm]) OR (“N-(phosphonomethyl)glycine trimethylsulfonium salt”[nm])) NOT ((“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb]) OR (“Roundup”[tw] AND (monsanto[tw] OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[MeSH Terms] OR “antifungal”[tw] OR “anti-fungal”[tw] OR “enzyme inhibitors”[Pharmacological Action] OR “enzyme inhibitors”[MeSH Terms] OR (“enzyme”[tw] AND inhibitor*[tw]) OR “enzyme inhibitors”[tw] OR “enzyme inhibitor”[tw] OR “herbicides”[Pharmacological Action] OR “herbicides”[MeSH Terms] OR “herbicides”[tw] OR “herbicide”[tw] OR “uncoupling agents”[Pharmacological Action] OR “uncoupling agents”[MeSH Terms] OR (“uncoupling”[tw] AND agent*[tw]) OR “uncoupling agent”[tw] OR “uncoupling agents”[tw] OR “pesticides”[mh] OR pesticide*[tw])))) OR ((“38641-94-0”[tw] OR “Glyphosate-isopropylammonium”[tw] OR “Glyphosate isopropylamine salt”[tw] OR “Azural AT”[tw] OR “CP 70139”[tw] OR “Fosulen”[tw] OR “Glifosato estrella”[tw] OR “Glycel”[tw] OR “Glycine, N-(phosphonomethyl)-, cmpd with 2-propanamine (1:1)”[tw] OR “Glyfos AU”[tw] OR “Glyfos BIO”[tw] OR “Glyphosate isopropylamine salt”[tw] OR “Glyphosate mono(isopropylamine) salt”[tw] OR “Glyphosate-isopropylammonium”[tw] OR “Glyphosate-mono(isopropylammonium)”[tw] OR “Landmaster”[tw] OR “MON 139”[tw] OR “MON 39”[tw] OR “N-(Phosphonomethyl)glycine isopropylamine salt”[tw] OR “N-(Phosphonomethyl)glycine isopropylammonium salt”[tw] OR “N-(Phosphonomethyl)glycine monoisopropylamine salt”[tw] OR “Nitosorg”[tw] OR “Ron-do”[tw] OR “Utal”[tw] OR “Utal (herbicide)”[tw] OR “Vision (herbicide)”[tw] OR “2-Propanamine, compd, with N-(phosphonomethyl)glycine (1:1)”[tw] OR “Glycine, N-(phosphonomethyl)-, compd. with 2-propanamine (1:1)”[tw] OR “N-(Phosphonomethyl)glycine, compound with 2-propylamine (1:1)”[tw] OR “Isopropylamine glyphosate”[tw] OR “81591-81-3”[tw] OR “Glyphosate-trimesium”[tw] OR “Glyphosphate-trimesium”[tw] OR “Avans 330”[tw] OR “Glyphosate mono(trimethylsulfonium) salt”[tw] OR “Glyphosate trimethylsulfonium salt”[tw] OR “Glyphosate-trimesium”[tw] OR “Medallon”[tw] OR “Ouragan”[tw] OR “R 50224”[tw] OR “SC 0224”[tw] OR “Sulfosate”[tw] OR “Sulphosate”[tw] OR “Touchdown herbicide”[tw] OR “Trimethylsulfonium carboxymethylamino-methylphosphonate”[tw] OR “Trimethylsulfonium glyphosate”[tw] OR “Glycine, N-(phosphonomethyl)-, ion(1-), trimethylsulfonium”[tw] OR “Sulfosate”[tw]) NOT ((“glyphosate”[nm]) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) AND (to[sh] OR po[sh] OR ae[sh] OR pk[sh] OR (me[sh] AND (“humans”[mh] OR “animals”[mh])) OR ci[sh] OR bl[sh] OR cf[sh] OR ur[sh] OR “environmental exposure”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR ((“Computational biology”[mh] OR “Medical Informatics”[mh] OR Genomics[mh] OR Genome[mh] OR Proteomics[mh] OR Proteome[mh] OR Metabolomics[mh] OR Metabolome[mh] OR Genes[mh] OR “Gene expression”[mh] OR Phenotype[mh] OR genetics[mh] OR genotype[mh] OR Transcriptome[mh] OR (“Systems Biology”[mh] AND (“Environmental Exposure”[mh] OR “Epidemiological Monitoring”[mh] OR analysis[sh])) OR “Transcription, Genetic ”[mh] OR “Reverse transcription”[mh] OR “Transcriptional activation”[mh] OR “Transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, Messenger”[mh] OR “RNA, Transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “Reverse Transcriptase Polymerase Chain Reaction”[mh] OR “Base Sequence”[mh] OR “Trans-activators”[mh] OR “Gene Expression Profiling”[mh])) OR cancer[sb] OR “pharmacology”[Majr])) OR ((“1071-83-6”[tw] OR “(Carboxymethylamino)methylphosphonic acid”[tw] OR “Carboxymethylaminomethanephosphinic acid”[tw] OR “C-K Yuyos FAV”[tw] OR “CP 67573”[tw] OR “Folusen”[tw] OR “Forsat”[tw] OR “Glialka”[tw] OR “Glifoglex”[tw] OR “Glifosan 747”[tw] OR “gliphosate”[tw] OR “Gliz”[tw] OR “Glyfos”[tw] OR “GlyGran”[tw] OR “Glyphodin A”[tw] OR “Glyphomax”[tw] OR “Glyphosate”[tw] OR “Glyphosphate”[tw] OR “Ground Bio”[tw] OR “Herbatop”[tw] OR “HM 2028”[tw] OR “Kickdown”[tw] OR “Lancer herbicide”[tw] OR “MON 2139”[tw] OR “MON 3539”[tw] OR “MON 6000”[tw] OR “N-(Phosphonomethyl)glycine”[tw] OR “N-(phosphonomethyl)-Glycine”[tw] OR “N-Phosphomethylglycine”[tw] OR “N-Phosphonomethylglycine”[tw] OR “Phorsat”[tw] OR “Phosphonomethylglycine”[tw] OR “Phosphonomethyliminoacetic acid”[tw] OR “Pondmaster”[tw] OR “Rebel Garden”[tw] OR “Roundup Max”[tw] OR “Safal”[tw] OR “Scout herbicide”[tw] OR “Silglif”[tw] OR “yerbimat”[tw]) NOT medline[sb]) OR (“Roundup”[tw] AND (monsanto[tw] OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[MeSH Terms] OR “antifungal”[tw] OR “anti-fungal”[tw] OR “enzyme inhibitors”[Pharmacological Action] OR “enzyme inhibitors”[MeSH Terms] OR (“enzyme”[tw] AND inhibitor*[tw]) OR “enzyme inhibitors”[tw] OR “enzyme inhibitor”[tw] OR “herbicides”[Pharmacological Action] OR “herbicides”[MeSH Terms] OR “herbicides”[tw] OR “herbicide”[tw] OR “uncoupling agents”[Pharmacological Action] OR “uncoupling agents”[MeSH Terms] OR (“uncoupling”[tw] AND agent*[tw]) OR “uncoupling agent”[tw] OR “uncoupling agents”[tw] OR “pesticides”[mh] OR pesticide*[tw])))) AND (2017/01/01 : 3000[dp])
BIOSIS; 9/2019 | CH=(Glyphosate OR “glyphosate isopropylamine” OR Glyphosphate OR “N-(phosphonomethyl)glycine ” OR “glycine, N-(phosphonomethyl)-, compound with 2-propanamine (1:1)” OR “phosphonomethyliminoacetic acid” OR “glyphosate acid” OR “glyphosate-isopropylammonium” OR “glyphosate mono(isopropylamine) salt” OR “glyphosate-mono(isopropylammonium)” OR “N-(phosphonomethyl)glycine, isopropylamine salt” OR Pondmaster OR “Roundup Max” OR Glifoglex OR Glycel OR ((Muster) AND (pesticide OR herbicide)) OR Rondo OR ((Sonic) AND (pesticide OR herbicide)) OR Spasor OR ((Sting) AND (pesticide OR herbicide)) OR Tumbleweed OR “MON-0573” OR “CP 67573” OR Roundup OR ((Rodeo) AND (pesticide OR herbicide)) OR Glifonox OR “MON-0139” OR “CP 70139” OR ((Shackle) AND (pesticide OR herbicide)) OR “1071-83-6” OR “38641-94-0”) Indexes=BCI Timespan=2017-2019
MEDLINE; 9/2019 | (“glyphosate” OR “1071-83-6” OR “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat” OR “Roundup” OR “34494-03-6” OR “MON 0459” OR “40465-66-5” OR “MON 14420” OR “MON 8750” OR “Roundup Hi-Load” OR “Roundup PRODry” OR “70393-85-0” OR “MON 8000” OR “Monsanto 8000” OR “Polado” OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate” OR “39600-42-5” OR “Glyphosate potassium” OR “Glyphosate monopotassium salt” OR “Glyphosate potassium” OR “Glyphosate-potassium” OR “Monopotassium glyphosate” OR “Roundup Attack” OR “Roundup Energy” OR “Roundup Maxload” OR “Roundup Original Max” OR “Roundup Power Max” OR “Roundup Ultramax II” OR “Roundup Weathermax” OR “Touchdown Forte HiTech” OR “Transorb R” OR “Weathermax” OR “Zapp Qi” OR “70901-12-1” OR “Glyphosate-potassium” OR “Potassium glyphosate” OR “Potassium N-(phosphonomethyl)glycine” OR “Uragan Forte” OR “VisionMAX” OR “N-(phosphonomethyl)glycine potassium salt” OR “114370-14-8” OR “Glyphosate ammonium” OR “N-(phosphonomethyl)glycine ammonium salt” OR “69254-40-6” OR “Glyphosate-diammonium” OR “Diammonium N-(phosphonomethyl)glycine” OR “N-(phosphonomethyl)glycine diammonium salt” ) AND MH ((“neoplasms” OR “carcinogenicity tests” OR “carcinogens” OR “cell division/drug effects” OR “cell cycle/drug effects” OR “cell line, tumor/drug effects” OR “gene expression regulation, neoplastic” OR “neoplasm proteins/drug effects” OR “angiogenesis inducing agents” OR “myelodysplastic-myeloproliferative diseases”) OR AB (cancer* OR carcinog* OR carcinom* OR cocarcinog* OR lymphoma* OR neoplas* OR oncogen* OR precancer* OR tumor* OR tumour*))
MEDLINE; 9/2019 | (“glyphosate, isopropyl amine salt” OR “N-(phosphonomethyl)glycine trimethylsulfonium salt” OR “38641-94-0” OR “Glyphosate-isopropylammonium” OR “Glyphosate isopropylamine salt” OR “Azural AT” OR “CP 70139” OR “Fosulen” OR “Glifosato estrella” OR “Glycel” OR “Glycine, N-(phosphonomethyl)-, cmpd with 2-propanamine (1:1)” OR “Glyfos AU” OR “Glyfos BIO” OR “Glyphosate isopropylamine salt” OR “Glyphosate mono(isopropylamine) salt” OR “Glyphosate-isopropylammonium” OR “Glyphosate-mono(isopropylammonium)” OR “Landmaster” OR “MON 139” OR “MON 39” OR “N-(Phosphonomethyl)glycine isopropylamine salt” OR “N-(Phosphonomethyl)glycine isopropylammonium salt” OR “N-(Phosphonomethyl)glycine monoisopropylamine salt” OR “Nitosorg” OR “Ron-do” OR “Utal” OR “Utal (herbicide)” OR “Vision (herbicide)” OR “2-Propanamine, compd, with N-(phosphonomethyl)glycine (1:1)” OR “Glycine, N-(phosphonomethyl)-, compd. with 2-propanamine (1:1)” OR “N-(Phosphonomethyl)glycine, compound with 2-propylamine (1:1)” OR “Isopropylamine glyphosate” OR “81591-81-3” OR “Glyphosate-trimesium” OR “Glyphosphate-trimesium” OR “Avans 330” OR “Glyphosate mono(trimethylsulfonium) salt” OR “Glyphosate trimethylsulfonium salt” OR “Glyphosate-trimesium” OR “Medallon” OR “Ouragan” OR “R 50224” OR “SC 0224” OR “Sulfosate” OR “Sulphosate” OR “Touchdown herbicide” OR “Trimethylsulfonium carboxymethylamino-methylphosphonate” OR “Trimethylsulfonium glyphosate” OR “Glycine, N-(phosphonomethyl)-, ion(1-), trimethylsulfonium” OR “Sulfosate” ) AND (MH (“neoplasms” OR “carcinogenicity tests” OR “carcinogens” OR “cell division/drug effects” OR “cell cycle/drug effects” OR “cell line, tumor/drug effects” OR “gene expression regulation, neoplastic” OR “neoplasm proteins/drug effects” OR “angiogenesis inducing agents” OR “myelodysplastic-myeloproliferative diseases”) OR AB(cancer* OR carcinog* OR carcinom* OR cocarcinog* OR lymphoma* OR neoplas* OR oncogen* OR precancer* OR tumor* OR tumour* ) )
MEDLINE; 9/2019 | AB (“glyphosate” OR “1071-83-6” OR “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat”) AND (MH (“humans” OR “animals” OR “environmental exposure” OR “endocrine system” OR “hormones, hormone substitutes, and hormone antagonists” OR “endocrine disruptors” OR “Computational biology” OR “Medical Informatics” OR Genomics OR Genome OR Proteomics OR Proteome OR Metabolomics OR Metabolome OR Genes OR “Gene expression” OR Phenotype OR genetics OR genotype OR Transcriptome OR “Systems Biology”) OR AB (“toxicity” OR “poisoning” OR “adverse effects” OR “pharmacokinetics” OR “metabolism” OR “chemically induced” OR “blood” OR “cerebrospinal fluid” OR “urine”)) AND MH ((“Environmental Exposure” OR “Epidemiological Monitoring” OR “Transcription, Genetic ” OR “Reverse transcription” OR “Transcriptional activation” OR “Transcription factors”) OR AB (Analysis OR Biosynthesis)) AND MH ((RNA OR DNA OR “RNA, Messenger” OR “RNA, Transfer” OR “peptide biosynthesis” OR “protein biosynthesis” OR “Reverse Transcriptase Polymerase Chain Reaction” OR “Base Sequence” OR “Trans-activators” OR “Gene Expression Profiling” OR “pharmacology”) OR AB (cancer OR “1071-83-6” OR “Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat”))
MEDLINE; 9/2019 | AB (“Roundup” ) AND (AB ((monsanto OR “antifungal agents” OR “anti-fungal” OR “antifungal” OR (“enzyme” AND inhibitor* ) OR “enzyme inhibitors” OR “enzyme inhibitor” OR “herbicides” OR “herbicide” OR (“uncoupling” AND agent* ) OR “uncoupling agent” OR “uncoupling agents” OR pesticide*) OR MH (“antifungal agents” OR “enzyme inhibitors” OR herbicides OR “uncoupling agents” OR pesticides)) (NOT ((“glyphosate” OR “1071-83-6” OR “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat” )) AND AB (“toxicity” OR “poisoning” OR “adverse effects” OR “pharmacokinetics” OR “metabolism”) AND (MH (“humans” OR “animals” OR “environmental exposure” OR “endocrine system” OR “hormones, hormone substitutes, and hormone antagonists” OR “endocrine disruptors” OR ((“Computational biology” OR “Medical Informatics” OR Genomics OR Genome OR Proteomics OR Proteome OR Metabolomics OR Metabolome OR Genes OR “Gene expression” OR Phenotype OR genetics OR genotype OR Transcriptome OR “Transcription, Genetic ” OR “Reverse transcription” OR “Transcriptional activation” OR “Transcription factors” OR “RNA, Messenger” OR “RNA, Transfer” OR “protein biosynthesis” OR “Reverse Transcriptase Polymerase Chain Reaction” OR “Base Sequence” OR “Trans-activators” OR “Gene Expression Profiling” OR “pharmacology”) OR AB (“chemically induced” OR “blood” OR “cerebrospinal fluid” OR “urine” OR cancer OR “1071-83-6” OR “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat” OR “peptide biosynthesis”) OR (AB(“biosynthesis”) AND MH(RNA OR DNA )) OR MH (“Systems Biology” AND (“Environmental Exposure” OR “Epidemiological Monitoring”))
MEDLINE; 9/2019 | AB (“34494-03-6” OR “MON 0459” OR “40465-66-5” OR “MON 14420” OR “MON 8750” OR “Roundup Hi-Load” OR “Roundup PRODry” OR “70393-85-0” OR “MON 8000” OR “Monsanto 8000” OR “Polado” OR “Trisodium hydrogen bis(N-(phosphonatomethyl)aminoacetate”) AND AB (“toxicity” OR “poisoning” OR “adverse effects” OR “pharmacokinetics” OR “metabolism”) AND (AB (“chemically induced” OR “blood” OR “cerebrospinal fluid” OR “urine”) OR MH (“humans” OR “animals” OR “environmental exposure” OR “endocrine system” OR “hormones, hormone substitutes, and hormone antagonists” OR “endocrine disruptors” OR “Computational biology” OR “Medical Informatics” OR Genomics OR Genome OR Proteomics OR Proteome OR Metabolomics OR Metabolome OR Genes OR “Gene expression” OR Phenotype OR genetics OR genotype OR Transcriptome OR “Systems Biology”)) AND MH ((“Environmental Exposure” OR “Epidemiological Monitoring” OR analysis )) OR “Transcription, Genetic ” OR “Reverse transcription” OR “Transcriptional activation” OR “Transcription factors” OR (“biosynthesis” AND (RNA OR DNA )) OR “RNA, Messenger” OR “RNA, Transfer” OR “peptide biosynthesis” OR “protein biosynthesis” OR “Reverse Transcriptase Polymerase Chain Reaction” OR “Base Sequence” OR “Trans-activators” OR “Gene Expression Profiling” OR “pharmacology”) OR AB (cancer))
MEDLINE; 9/2019 | (“39600-42-5” OR “Glyphosate potassium” OR “Glyphosate monopotassium salt” OR “Glyphosate potassium” OR “Glyphosate-potassium” OR “Monopotassium glyphosate” OR “Roundup Attack” OR “Roundup Energy” OR “Roundup Maxload” OR “Roundup Original Max” OR “Roundup Power Max” OR “Roundup Ultramax II” OR “Roundup Weathermax” OR “Touchdown Forte HiTech” OR “Transorb R” OR “Weathermax” OR “Zapp Qi” OR “70901-12-1” OR “Glyphosate-potassium” OR “Potassium glyphosate” OR “Potassium N-(phosphonomethyl)glycine” OR “Uragan Forte” OR “VisionMAX” OR “N-(phosphonomethyl)glycine potassium salt” OR “114370-14-8” OR “Glyphosate ammonium” OR “N-(phosphonomethyl)glycine ammonium salt” OR “69254-40-6” OR “Glyphosate-diammonium” OR “Diammonium N-(phosphonomethyl)glycine” OR “N-(phosphonomethyl)glycine diammonium salt” ) NOT ((“glyphosate” ) OR ((“1071-83-6” OR “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat”) AND AB (“toxicity” OR “poisoning” OR “adverse effects” OR “pharmacokinetics” OR “metabolism”) AND MH ((“humans” OR “animals” OR “environmental exposure” OR “endocrine system” OR “hormones, hormone substitutes, and hormone antagonists” OR “endocrine disruptors” OR ((“Computational biology” OR “Medical Informatics” OR Genomics OR Genome OR Proteomics OR Proteome OR Metabolomics OR Metabolome OR Genes OR “Gene expression” OR Phenotype OR genetics OR genotype OR Transcriptome OR (“Systems Biology” OR (AB (“chemically induced” OR “blood” OR “cerebrospinal fluid” OR “urine”)) AND MH(“Environmental Exposure” OR “Epidemiological Monitoring” OR analysis )) OR “Transcription, Genetic ” OR “Reverse transcription” OR “Transcriptional activation” OR “Transcription factors”) OR AB (“biosynthesis”)) AND (RNA OR DNA OR “RNA, Messenger” OR “RNA, Transfer” OR “peptide biosynthesis” OR “protein biosynthesis” OR “Reverse Transcriptase Polymerase Chain Reaction” OR “Base Sequence” OR “Trans-activators” OR “Gene Expression Profiling” OR “pharmacology” OR “antifungal agents”[Pharmacological Action] OR “antifungal agents”[ Terms] OR “antifungal” OR “anti-fungal” OR “enzyme inhibitors” OR AB (cancer OR “1071-83-6” OR “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “NPhosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat” OR “Roundup”) AND AB (monsanto OR “enzyme”) AND AB ((inhibitor* OR “enzyme inhibitors” OR “enzyme inhibitor” OR “herbicides” OR “herbicide” OR “uncoupling agents” OR “uncoupling”) OR MH (herbicides OR “uncoupling agents”)) AND AB (agent* OR “uncoupling agent” OR “uncoupling agents” OR Pesticide*) OR MH (Pesticides)
MEDLINE; 9/2019 | (TX (“glyphosate, isopropyl amine salt” OR “N-(phosphonomethyl)glycine trimethylsulfonium salt”) ) NOT TX (“glyphosate”) OR ( TX (“1071-83-6”OR “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid”OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden”OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat”) ) AND ( MH (“humans” OR “animals”) OR MH (“environmental exposure” OR “endocrine system” OR “hormones, hormone substitutes, and hormone antagonists” OR “endocrine disruptors”) OR MH (“Computational biology” OR “Medical Informatics” OR Genomics OR Genome OR Proteomics OR Proteome OR Metabolomics OR Metabolome OR Genes OR “Gene expression” OR Phenotype OR genetics OR genotype OR Transcriptome OR “Transcription, Genetic ” OR “Reverse transcription” OR “Transcriptional activation” OR “Transcription factors” OR “RNA, Messenger” OR “RNA, Transfer” OR “peptide biosynthesis” OR “protein biosynthesis” OR “Reverse Transcriptase Polymerase Chain Reaction” OR “Base Sequence” OR “Trans-activators” OR “Gene Expression Profiling”) OR MH (“Systems Biology”) ) AND ( MH (“Environmental Exposure” OR “Epidemiological Monitoring”) OR MW (analysis) OR MW (“biosynthesis”) ) AND ( MH (RNA OR DNA) OR AB (cancer) OR MM (“pharmacology”) ) AND ( MH (“humans” OR “animals”) OR MH (“environmental exposure” OR “endocrine system” OR “hormones, hormone substitutes, and hormone antagonists” OR “endocrine disruptors” OR ((“Computational biology” OR “Medical Informatics” OR Genomics OR Genome OR Proteomics OR Proteome OR Metabolomics OR Metabolome OR Genes OR “Gene expression” OR Phenotype OR genetics OR genotype OR Transcriptome OR (“Systems Biology” AND (“Environmental Exposure” OR “Epidemiological Monitoring”) OR MW (analysis) OR MH (“Transcription, Genetic” OR “Reverse transcription” OR “Transcriptional activation” OR “Transcription factors”) OR MW (“biosynthesis”) ) AND ( MH ((RNA OR DNA) OR “RNA, Messenger” OR “RNA, Transfer” OR “peptide biosynthesis” OR “protein biosynthesis” OR “Reverse Transcriptase Polymerase Chain Reaction” OR “Base Sequence” OR “Trans-activators” OR “Gene Expression Profiling”) OR AB (cancer) OR MM (“pharmacology”) OR TX ((“1071-83-6” OR “(Carboxymethylamino)methylphosphonic acid” OR “Carboxymethylaminomethanephosphinic acid” OR “C-K Yuyos FAV” OR “CP 67573” OR “Folusen” OR “Forsat” OR “Glialka” OR “Glifoglex” OR “Glifosan 747” OR “gliphosate” OR “Gliz” OR “Glyfos” OR “GlyGran” OR “Glyphodin A” OR “Glyphomax” OR “Glyphosate” OR “Glyphosphate” OR “Ground Bio” OR “Herbatop” OR “HM 2028” OR “Kickdown” OR “Lancer herbicide” OR “MON 2139” OR “MON 3539” OR “MON 6000” OR “N-(Phosphonomethyl)glycine” OR “N-(phosphonomethyl)-Glycine” OR “N-Phosphomethylglycine” OR “N-Phosphonomethylglycine” OR “Phorsat” OR “Phosphonomethylglycine” OR “Phosphonomethyliminoacetic acid” OR “Pondmaster” OR “Rebel Garden” OR “Roundup Max” OR “Safal” OR “Scout herbicide” OR “Silglif” OR “yerbimat”) OR TX (“Roundup” AND (Monsanto)) OR MH (“antifungal agents”)OR TX (“antifungal” OR “anti-fungal”) OR MH (“enzyme inhibitors”) OR TX (“enzyme” AND inhibitor*) OR TX (“enzyme inhibitors” OR “enzyme inhibitor”)OR MH (“herbicides”) OR TX (“herbicides” OR “herbicide”) OR MH (“uncoupling agents”) OR TX (“uncoupling” AND agent*) OR TX (“uncoupling agent” OR “uncoupling agents”) OR MH (“pesticides” OR pesticide*) )
SciFinder; 9/2019 | Substance Identifier “1071-83-6; 38641-94-0; Glyphos…”>substances (27)>get references (19597)>refine “2017-2019” (2591)>refine “Clinical Trial Dissertation Jo…” (1111)>remove 198 references (913)

The results of the 2019 updated literature review were:

- Number of records identified (after duplicate removal): 2,636
- Number of records identified from government websites: 0
- Total number of records to undergo literature screening: 2,636

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on glyphosate:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and/or abstract clearly indicated that the study was not relevant to the toxicological profile.

2015/2017 literature review:

- Number of titles and abstracts screened: 5,803
- Number of studies considered relevant and moved to the next step: 628

2019 literature review

- Number of titles and abstracts screened: 2,636
- Number of studies considered relevant and moved to the next step: 135

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

2015/2017 literature review:

- Number of studies undergoing full text review: 628
- Total number of studies cited in the profile: 329

2019 literature review:

- Number of studies undergoing full text review: 135
- Total number of studies cited in the profile: 60

A summary of the results of the literature search and screening is presented in Figure B-1- and Figure B-2..

Figure B-1 February 2015 and September 2017 Literature Search Results and Screen for Glyphosate

Diagram of the literature and search screen results. Of the number of studies cited (329), 118 were chemistry studies, 207 were toxocoligy studies, and 16 were regulatory studies.

Figure B-2 September 2019 Supplemental Literature Search Results and Screen for Glyphosate

Graph of studies identified via database search. In all, there were 89 studies for qualitative review out of 2,636 records originally screened.