# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

Human exposure to glyphosate formulations via its use in weed control includes exposure to all substances in a particular glyphosate formulation. No MRLs were derived for glyphosate formulations due to the wide variation in glyphosate content and surfactants used in various glyphosate formulations and the fact that surfactants can contribute to the toxicity of glyphosate formulations. However, the general population may be exposed via food or water sources containing glyphosate residues from glyphosate-based formulations registered for use in agricultural and residential environments. Therefore, health effects data associated with oral exposure to glyphosate technical are considered relevant to potential derivation of oral MRLs for glyphosate.

## Glyphosate technical Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glyphosate technical
CAS Numbers: | 1071-83-6
Date: | August 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No acute-duration inhalation exposure-response studies were identified for glyphosate.

Agency Contact (Chemical Manager): Hana R. Pohl, M.D., Ph.D.

## Glyphosate technical Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glyphosate technical
CAS Numbers: | 1071-83-6
Date: | August 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation exposure-response studies were identified for glyphosate.

Agency Contact (Chemical Manager): Hana R. Pohl, M.D., Ph.D.

## Glyphosate technical Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glyphosate technical
CAS Numbers: | 1071-83-6
Date: | August 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation exposure-response studies were identified for glyphosate.

Agency Contact (Chemical Manager): Hana R. Pohl, M.D., Ph.D.

## Glyphosate technical Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glyphosate technical
CAS Numbers: | 1071-83-6
Date: | August 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 1 mg/kg/day
Critical Effect: | Gastrointestinal effects
Reference: | EPA 2017b
Point of Departure: | NOAEL of 100 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 7
Species: | Rabbit

MRL Summary: An acute-duration oral MRL of 1 mg/kg/day was derived for glyphosate based on gastrointestinal effects (diarrhea, few feces) observed in pregnant female New Zealand white rabbits administered glyphosate acid (96.5% purity) by daily gavage (in deionized water) during GDs 8–20 (EPA 2017b). The MRL is based on a NOAEL of 100 mg/kg/day and a total uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

Selection of the Critical Effect: Several acute-duration oral studies were available regarding the toxicity of glyphosate technical following acute-duration oral exposure (see Table A-1). The lowest LOAELs were 175 mg/kg/day for gastrointestinal effects (diarrhea, few feces) in maternal rabbits and 300 mg/kg/day for developmental effects (depressed fetal weight) following gavage treatment with glyphosate technical during GDs 8–20 at 175 mg/kg/day. Based on available data, gastrointestinal disturbance is considered to represent the most sensitive effect of glyphosate toxicity following oral exposure in laboratory animals.

Table A-1 NOAELs and LOAELs Identified in Acute-Duration Oral Studies of Glyphosate Technical

Endpoint | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Body weight | 28.5% depressed maternal body weight gain in rats | 1,000 | 3,500 | EPA 1992e
Body weight | No effect in pregnant rats | 1,000 | | EPA 2017b
Body weight | No effect in pregnant rabbits | 300 | | EPA 2017b
Gastrointestinal | Diarrhea in 2/8 rats gavaged once | | 2,000 | Adam et al. 1997
Gastrointestinal | Diarrhea in rats gavaged once | 1,000 | 2,000 | EPA 2013c
Gastrointestinal | Diarrhea, soft stools in pregnant rats gavaged on GDs 6–19 | 1,000 | 3,500 | EPA 1992e
Gastrointestinal | Diarrhea, few feces in pregnant rabbits gavaged on GDs 8–20 | 100 | 175 | EPA 2017b
Developmental | Decreased fetal weight; delayed ossification | 1,000 | 3,500 | EPA 1992e
Developmental | No effect in fetuses from pregnant rats gavaged on GDs 7–16 | 1,000 | | EPA 2017b
Developmental | Depressed weight in fetuses from pregnant rabbits gavaged on GDs 8–20 | 175 | 300 | EPA 2017b
Other | Hypothermia in rats gavaged once | 1,000 | 2,000 | EPA 2013c

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: Among available acute-duration oral toxicity studies for glyphosate, the developmental toxicity study in rabbits (EPA 2017b) identified the lowest LOAEL (gastrointestinal effects in pregnant rabbits gavaged with glyphosate acid); the corresponding NOAEL was 100 mg/kg/day. Therefore, this study was selected as the principal study for deriving an acute-duration oral MRL for glyphosate.

Summary of the Principal Study:

EPA. 2017b. Memorandum. December 13, 2017. Glyphosate: Preparation of data evaluation records for developmental rat and rabbit toxicity studies. MRID No.: 43320615, 43320616. Washington, DC: U.S. Environmental Protection Agency, Office of Chemical Safety and Pollution Prevention.

Groups of sperm-positive female New Zealand white rabbits (20/group) were administered glyphosate acid (95.6% active ingredient) by daily gavage (in deionized water vehicle; dosing volume 2 mL/kg body weight) on GDs 8–20 at target concentrations of 0, 100, 175, or 300 mg/kg/day (adjusted for purity of active ingredient). Dams were monitored for survival, clinical signs, body weight, and food intake. On GD 30, dams were sacrificed and subjected to gross external and internal examination, pregnancy status, weight of gravid uteri, number of corpora lutea, number and position of implantations, live fetuses, and early and late intrauterine deaths. Fetuses were evaluated for weight and sex. External, visceral, and skeletal examinations were performed; brains were subjected to macroscopic examination.

The 100 mg/kg/day dose level represented a NOAEL for maternal toxicity. At 175 and 300 mg/kg/day, maternal rabbits exhibited diarrhea and reduced production of feces. Mean body weight in the 300 mg/kg/day group of maternal rabbits ranged from 5.2 to 7.4% less than that of controls during GDs 16–26. The depressed maternal body weight was <10% in magnitude, and was therefore not considered to represent an adverse effect. Furthermore, there were no statistically significant differences between controls and glyphosate-treated groups regarding GD 30 mean maternal body weight. Gross pathologic examination of maternal rabbits revealed no treatment-related effects. There were no treatment-related effects on pregnancy rate, numbers of corpora lutea, total number of implantation sites, litter size, sex ratio, or pre- or post-implantation loss. The 300 mg/kg/day dose group exhibited 8.3% lower mean fetal weight (p<0.05). Gross and visceral examination of fetuses revealed no treatment-related effects. Increased incidences of fetuses with selected minor skeletal defects (e.g., delayed sternebral and vertebral ossification) were observed at the 300 mg/kg/day maternal dose level. However, incidences of these skeletal defects did not appear to be increased in glyphosate-treated groups when evaluated on a per litter basis; therefore, they were not considered treatment-related developmental effects.

Selection of the Point of Departure: Incidence data for the gastrointestinal effects were not presented in the available data evaluation record (DER) for the study, thus precluding a benchmark dose (BMD) approach to deriving an MRL. Therefore, the NOAEL of 100 mg/kg/day was selected as the point of departure for deriving an acute-duration oral MRL for glyphosate.

Uncertainty Factor: The NOAEL of 100 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

Other Additional Studies or Pertinent Information: Glyphosate-induced gastrointestinal effects were observed in acute-duration oral studies of rats (Adam et al. 1997; EPA 1992e, 2013c), although rabbits appear to be much more sensitive than rats to glyphosate-induced gastrointestinal effects following oral dosing.

Agency Contacts (Chemical Managers): Hana R. Pohl, M.D., Ph.D.

## Glyphosate technical Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glyphosate technical
CAS Numbers: | 1071-83-6
Date: | August 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: The chronic-duration oral MRL of 1 mg/kg/day is adopted as the intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: Several intermediate-duration oral animal studies were available for glyphosate technical (see Table A-2).

Table A-2 NOAELs and LOAELs Identified in Intermediate-Duration Oral Studies of Glyphosate Technical

Endpoint | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Body weight | 12–18% depressed paternal body weight gain in rats | M: 754 | M: 2,219 | EPA 1992a
Body weight | 12–18% depressed paternal body weight gain in rats | F: 802 | F: 3,134 | EPA 1992a
Body weight | No effect in rats (highest dose) | M, F: 30 | | EPA 1992g
Body weight | No effect in rats (highest dose) | M: 1,234 | | EPA 2013a
Body weight | No effect in rats (highest dose) | F: 1,273 | | EPA 2013a
Body weight | 18% lower mean body weight and body weight gain in male rats | M: 1,678 | M: 3,393 | NTP 1992
Body weight | 18% lower mean body weight and body weight gain in male rats | F: 3,393 | | NTP 1992
Body weight | No effect in mice (highest dose) | F: 1,447.5 | | EPA 2013b
Body weight | 10–11% lower mean final body weight in mice | M: 2,273 | M: 4,776 | NTP 1992
Body weight | 10–11% lower mean final body weight in mice | F: 5,846 | F: 11,977 | NTP 1992
Body weight | No effect in maternal rabbits (highest dose) | F: 350 | | EPA 1992f
Gastrointestinal | Soft stool in rats | M: 754 | M: 2,219 | EPA 1992a
Gastrointestinal | Soft stool in rats | F: 802 | F: 3,134 | EPA 1992a
Gastrointestinal | Increased severity of basophilia and hypertrophy of acinar cells in parotid and submandibular salivary glands of rats | M: 205 | M: 410 | NTP 1992
Gastrointestinal | Increased severity of basophilia and hypertrophy of acinar cells in parotid and submandibular salivary glands of rats | F: 213 | F: 421 | NTP 1992
Gastrointestinal | Increased severity of basophilia of acinar cells in parotid salivary gland of mice | M: 1,065 | M: 2,273 | NTP 1992
Gastrointestinal | Increased severity of basophilia of acinar cells in parotid salivary gland of mice | F: 1,411 | F: 2,707 | NTP 1992
Gastrointestinal | Increased incidence of soft stool and/or diarrhea in pregnant rabbits | 175 | 350 | EPA 1992f
Hematological | No effect in rats (highest dose) | M, F: 3,393 | | NTP 1992
Hepatic | No effect in rats (highest dose) | M: 1,234 | | EPA 2013a
Hepatic | No effect in rats (highest dose) | F: 1,273 | | EPA 2013a
Hepatic | M: Increases in liver weight and serum ALT | M: 811 | M: 1,678 | NTP 1992
Hepatic | F: Increases in liver weight and serum AP, ALT, and bile acids | F: 1,690 | F: 3,393 | NTP 1992
Hepatic | No effect in mice | M: 10,780 | | NTP 1992
Hepatic | No effect in mice | F: 11,977 | | NTP 1992
Renal | No effect in rats (highest dose) | M: 1,234 | | EPA 2013a
Renal | No effect in rats (highest dose) | F: 1,273 | | EPA 2013a
Immunological | No effect in mice (highest dose) | F: 1,447.5 | | EPA 2013b
Neurological | No effect in rats (highest dose) | M: 1,546.5 | | EPA 2013c
Neurological | No effect in rats (highest dose) | F: 1,630.6 | | EPA 2013c
Reproductive | No effect in rats (highest dose) | M: 2,219 | | EPA 1992a
Reproductive | No effect in rats (highest dose) | F: 3,234 | | EPA 1992a
Reproductive | No effect in rats (highest dose) | M, F: 30 | | EPA 1992g
Reproductive | No effect in rats (highest dose) | M: 1,234 | | EPA 2013a
Reproductive | No effect in rats (highest dose) | F: 1,273 | | EPA 2013a
Developmental | 14–20% depressed pup body weight during lactation (maternally toxic dose level) | 802 | 3,134 | EPA 1992a
Developmental | Delayed preputial separation | 408 | 1,234 | EPA 2013a
Developmental | No effect in rabbits (highest dose) | 350 | | EPA 1992f

ALT = alanine aminotransferase; AP = alkaline phosphatase; F = female; LOAEL = lowest-observed-adverse-effect level; M = male; NOAEL = no-observed-adverse-effect level

Increased incidence of kidney tubular dilation was reported for F3b male weanlings of a 3-generation study of glyphosate technical (98.7% purity) administered to male and female Sprague-Dawley rats in the diet at an estimated dose level of 30 mg/kg/day; the reported NOAEL was 10 mg/kg/day (EPA 1992g). However, there were no signs of treatment-related effects on kidneys of rat offspring in two subsequent 2-generation rat studies at dietary doses up to 1,234 or 1,273 mg/kg/day for parental males and females, respectively (EPA 2013a), or 2,633 or 3,134 mg/kg/day for parental males and females, respectively (EPA 1992a). Therefore, the finding of increased incidence of kidney tubular dilation in the 3-generation rat study (EPA 1992g) was considered a spurious result rather than a glyphosate-induced adverse developmental effect. In one 2-generation oral rat study, exposure via the diet at estimated parental dose levels of 1,234 or 1,273 mg/kg/day (parental males and females, respectively) resulted in delayed preputial separation in male pups (EPA 2013a). In the other 2-generation study, the highest dietary dose level (up to 2,633 and 3,134 mg/kg/day for parental males and females, respectively) resulted in up to 14–20% depressed pup body weight and/or body weight gain during the lactation period (EPA 1992a). There were no apparent treatment-related developmental effects in a study of rabbits treated by gavage at up to 350 mg/kg/day during GDs 6–27 (EPA 1992f).

Consideration was given to the increased anogenital distance (AGD) reported by Manservisi et al. (2019). This pilot study found that male F1 Sprague-Dawley rats exposed to 1.75 mg/kg/day glyphosate technical from gestation day 6 to post-natal day 120 showed increased anogenital distance at postnatal day 4. However, this result was determined to be insufficient for MRL derivation. The study used only one dose, which was substantially lower than the other lowest observed adverse effect levels (LOAELs) and the no observed adverse effect levels (NOAELs) identified in the body of literature. Furthermore, while decreases in AGD are sometimes considered an adverse effect related to endocrine disruption, increases in AGD are less commonly used because the toxicological significance of such increases is not well understood (Schwartz et al. 2019). Given that only one dose was tested, the observed effect was small (6%) and not observed in other studies, and because the relevance of such an effect to human health is not well-understood, it is not appropriate to use this study for MRL derivation.

As shown in Table A-2, gastrointestinal endpoints are the most sensitive to intermediate-duration oral exposure of laboratory animals to glyphosate technical. Pregnant rabbits gavaged with glyphosate technical daily at 350 mg/kg/day (LOAEL) during GDs 6–27 exhibited increased incidence of soft stool and/or diarrhea; the NOAEL was 175 mg/kg/day (EPA 1992f). Similar results were observed among other pregnant rabbits gavaged daily with glyphosate technical at 175 mg/kg/day (LOAEL) during GDs 8–20 (an acute-duration oral exposure scenario); the NOAEL was 100 mg/kg/day (EPA 2017b).

Increased severity of basophilia and hypertrophy of acinar cells in parotid and submandibular salivary glands were observed among male and female rats receiving glyphosate from the diet for 13 weeks at 410 and 421 mg/kg/day, respectively; NOAELs were 205 and 213 mg/kg/day, respectively (NTP 1992). Increased severity of basophilia of acinar cells in parotid salivary glands were observed in male and female mice similarly treated at estimated doses of 2,273 and 2,707 mg/kg/day, respectively; NOAELs were 507 and 753 mg/kg/day, respectively (NTP 1992). Thus, rats appear to be much more sensitive than mice to glyphosate treatment-related effects on salivary glands.

Among reliable animal study results, the LOAEL of 350 mg/kg/day for gastrointestinal effects (increased incidence of soft stool and/or diarrhea) in maternal rabbits gavaged daily during GDs 6–27 represents the most sensitive adverse effect from intermediate-duration oral exposure to glyphosate technical (EPA 1992f); the corresponding NOAEL is 175 mg/kg/day (see Table A-2). Incidence and severity data were not available for review. Application of a NOAEL/LOAEL approach using the NOAEL of 175 mg/kg/day as the point of departure and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) would result in an intermediate-duration oral MRL of 2 mg/kg/day (rounded up from 1.75 mg/kg/day). An intermediate-duration oral MRL was not derived for glyphosate because an intermediate-duration oral MRL of 2 mg/kg/day is higher than the acute- and chronic-duration oral MRL of 1 mg/kg/day. Glyphosate-induced microscopic changes in salivary glands of the rats treated orally for 13 weeks are not considered an adequate basis for MRL derivation due to uncertainty regarding the adversity of the effect. However, application of a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) to the NOAEL of 205 mg/kg/day for salivary gland changes in male rats administered glyphosate in the diet for 13 weeks would result in an intermediate-duration oral MRL of 2 mg/kg/day. The chronic-duration oral MRL of 1 mg/kg/day for glyphosate is adopted as the intermediate-duration oral MRL because 1 mg/kg/day is considered protective of intermediate-duration oral exposure to glyphosate as well.

Agency Contact (Chemical Manager): Hana R. Pohl, M.D., Ph.D.

## Glyphosate technical Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glyphosate technical
CAS Numbers: | 1071-83-6
Date: | August 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 1 mg/kg/day
Critical Effect: | Inflammation of gastric squamous mucosa
Reference: | EPA 1991a, 1991b
Point of Departure: | NOAEL of 113 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 19
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 1 mg/kg/day was derived for glyphosate based on gastrointestinal effects (inflammation of gastric squamous mucosa) observed in female rats administered glyphosate technical in the diet for up to 24 months at an estimated dose of 457 mg/kg/day; the NOAEL was 113 mg/kg/day (EPA 1991a, 1991b). The MRL is based on a NOAEL of 113 mg/kg/day and a total uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

Selection of the Critical Effect: Several chronic-duration oral animal studies were available for glyphosate technical (see Table A-3).

Table A-3 NOAELs and LOAELs Identified in Chronic-Duration Oral Studies of Glyphosate Technical

Endpoint | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Body weight | 13% lower body weight in female rats at treatment week 81 | M: 940 | | EPA 1991a, 1991b
Body weight | 13% lower body weight in female rats at treatment week 81 | F: 457 | F: 1,183 | EPA 1991a, 1991b
Body weight | No effect in rats (highest dose) | M: 31.45 | | EPA 1992d
Body weight | No effect in rats (highest dose) | F: 34.02 | | EPA 1992d
Body weight | No effect in rats (highest dose) | M: 1,214 | | EPA 2013a
Body weight | No effect in rats (highest dose) | F: 1,498 | | EPA 2013a
Body weight | 11–14% lower body weight and body weight gain in rats | 300 | 1,000 | EPA 2015c
Body weight | No effect in mice (highest dose) | M: 4,945 | | EPA 2015a
Body weight | No effect in mice (highest dose) | F: 6,069 | | EPA 2015a
Body weight | No effect in mice (highest dose) | 1,000 | | EPA 2015c
Body weight | No effect in dogs (highest dose) | 500 | | EPA 1986a, 1987
Gastrointestinal | Inflammation of gastric squamous mucosa | M: 940 | | EPA 1991a, 1991b
Gastrointestinal | Inflammation of gastric squamous mucosa | F: 113 | F: 457 | EPA 1991a, 1991b
Gastrointestinal | No effect in rats (highest dose) | M: 31.45 | | EPA 1992d
Gastrointestinal | No effect in rats (highest dose) | F: 34.02 | | EPA 1992d
Gastrointestinal | Increased severity of basophilia and hypertrophy of acinar cells in parotid and mandibular salivary gland in rats | 100 | 300 | EPA 2015c
Gastrointestinal | No effect in mice (highest dose) | M: 4,945 | | EPA 2015a
Gastrointestinal | No effect in mice (highest dose) | F: 6,069 | | EPA 2015a
Hematological | No effect in rats (highest dose) | M: 940 | | EPA 1991a, 1991b
Hematological | No effect in rats (highest dose) | F: 1,183 | | EPA 1991a, 1991b
Hematological | No effect in rats (highest dose) | M: 31.45 | | EPA 1992d
Hematological | No effect in rats (highest dose) | F: 34.02 | | EPA 1992d
Hematological | No effect in rats (highest dose) | M: 1,214 | | EPA 2015c
Hematological | No effect in rats (highest dose) | F: 1,498 | | EPA 2015c
Hematological | No effect in rats (highest dose) | 1,000 | | EPA 2015c
Hematological | No effect in mice (highest dose) | M: 4,945 | | EPA 2015a
Hematological | No effect in mice (highest dose) | F: 6,069 | | EPA 2015a
Hematological | No effect in dogs (highest dose) | 500 | | EPA 1986a, 1987
Hepatic | No effect in rats (highest dose) | M: 940 | | EPA 1991a, 1991b
Hepatic | No effect in rats (highest dose) | F: 1,183 | | EPA 1991a, 1991b
Hepatic | No effect in rats (highest dose) | M: 31.45 | | EPA 1992d
Hepatic | No effect in rats (highest dose) | F: 34.02 | | EPA 1992d
Hepatic | Increased serum AP, ALT, bilirubin in male rats; increased serum AP, ALT in female rats | M: 361 | M: 1,214 | EPA 2015c
Hepatic | Increased serum AP, ALT, bilirubin in male rats; increased serum AP, ALT in female rats | F: 437 | F: 1,498 | EPA 2015c
Hepatic | No effect in rats | 1,000 | | EPA 2015c
Hepatic | Centrilobular hepatocellular necrosis in male rats | M: 835 | M: 4,945 | EPA 2015a
Hepatic | Centrilobular hepatocellular necrosis in male rats | F: 6,069 | | EPA 2015a
Hepatic | No effect in mice (highest dose) | 1,000 | | EPA 2015c
Renal | Increased specific gravity, decreased pH of urine in male rats | M: 362 | M: 940 | EPA 1991a, 1991b
Renal | Increased specific gravity, decreased pH of urine in male rats | F: 1,183 | | EPA 1991a, 1991b
Renal | No effect in rats (highest dose) | M: 31.45 | | EPA 1992d
Renal | No effect in rats (highest dose) | F: 34.02 | | EPA 1992d
Renal | M: Decreased pH of urine in rats | M: 361 | M: 1,214 | EPA 2015c
Renal | M, F: Papillary necrosis in kidney in rats | F:437 | F: 1,498 | EPA 2015c
Renal | Decreased pH of urine in male rats | M: 300 | M: 1,000 | EPA 2015c
Renal | Decreased pH of urine in male rats | F: 1,000 | | EPA 2015c
Renal | Renal tubular epithelial basophilia in female mice | M: 4,945 | | EPA 2015a
Renal | Renal tubular epithelial basophilia in female mice | F: 968 | F: 6,069 | EPA 2015a
Renal | No effect in mice (highest dose) | 1,000 | | EPA 2015c
Ocular | Lens abnormalities in male rats | M: 362 | M: 940 | EPA 1991a, 1991b
Ocular | Lens abnormalities in male rats | F: 1,183 | | EPA 1991a, 1991b
Ocular | No effect in rats | M: 1,214 | | EPA 2015c
Ocular | No effect in rats | F: 1,498 | | EPA 2015c
Ocular | No effect in rats | 1,000 | | EPA 2015c
Ocular | No effect in dogs (highest dose) | 500 | | EPA 1986a, 1987
Neurological | No effect in rats (highest dose) | M: 1,214 | | EPA 2013c
Neurological | No effect in rats (highest dose) | F: 1,498 | | EPA 2013c

ALT = alanine aminotransferase; AP = alkaline phosphatase; F = female; LOAEL = lowest-observed-adverse-effect level; M = male; NOAEL = no-observed-adverse-effect level

As shown in Table A-3, gastrointestinal endpoints are the most sensitive to chronic-duration oral exposure of laboratory animals to glyphosate technical. Inflammation of gastric squamous mucosa was observed in female (but not male) rats administered glyphosate technical in the diet for up to 24 months at an estimated dose of 457 mg/kg/day; the NOAEL was 113 mg/kg/day (EPA 1991a, 1991b). Increased severity of cytoplasmic changes in salivary gland cells (basophilia and hypertrophy of acinar cells in parotid and submandibular salivary glands) was reported for rats receiving glyphosate from the diet for 2 years at doses ≥300 mg/kg/day (EPA 2015c). Although salivary gland cytoplasmic changes were noted in rats at doses <300 mg/kg/day as well, the changes were reported to be only of minimal or mild severity; therefore, they are not considered adverse effects. Furthermore, the toxicological significance of the glyphosate treatment-related effects on salivary glands is uncertain. One chronic-duration oral study of male and female mice found no evidence of glyphosate treatment-related gastrointestinal effects at doses as high as 4,945 and 6,069 mg/kg/day, respectively (EPA 1985a, 1985b, 1986b, 1989, 1991c, 1993, 2015a).

Summary of the Principal Study:

EPA. 1991a. June 03, 1991. Memorandum. 40 Page(s). William Dykstra. Toxicology Branch. Glyphosate; 2-Year combined chronic toxicity/carcinogenicity study in Sprague-Dawley rats - List A Pesticide for Reregistration Pages 29-40 removed-registrant data. MRID 416438-01. Tox review 008390. U.S. Environmental Protection Agency. https://archive.epa.gov/pesticides/chemicalsearch/chemical/foia/web/pdf/103601/103601-263.pdf. April 10, 2016.

EPA. 1991b. December 13, 1991. Memorandum. 38 Page(s). William Dykstra. Toxicology Branch I. Glyphosate - EPA Registration No. 524-308 - 2-Year chronic feeding/oncogenicity study in rats with technical glyphosate. MRID 416438-01. Tox review 008897. U.S. Environmental Protection Agency. https://archive.epa.gov/pesticides/chemicalsearch/chemical/foia/web/pdf/103601/103601-268.pdf. April 10, 2016.

Groups of albino Sprague Dawley rats (60/sex/group) were administered technical glyphosate (96.5% purity) in the diet at target concentrations of 0, 2,000, 8,000, or 20,000 ppm (mean measured concentrations of 0, 1,900, 7,600, and 19,000 ppm, respectively) for up to 24 months. Rats were monitored for survival, clinical signs, food intake, and body weight. Ten rats/sex/dose were subjected to comprehensive evaluations at 12-month interim sacrifice. Rats were subjected to ophthalmologic examinations prior to the initiation of treatment and twice prior to scheduled terminal sacrifice. Blood and urine samples were collected at 6, 12, 18, and 24 months for hematology, clinical chemistry, and urinalysis. Evaluations of all rats that died or survived until scheduled sacrifice included organ weight determinations (brain, liver, kidneys, testes, epididymides, prostate) and comprehensive gross and histopathologic examinations.

There were no indications of glyphosate-related clinical signs or effects on survival. Mean body weights of all glyphosate-treated male rats were not significantly different from that of controls. Mean body weights and of high-dose female rats were significantly lower than that of controls at weeks 7, 13, 81, and 104 (approximately 3–4% less than that of controls); by week 81, the magnitude of the mean body weight difference between high-dose females and their controls reached 13% (470.6 g versus 543.2 g for controls). There were no significant differences between controls and glyphosate-treated groups regarding food consumption. Based on mean body weight and food consumption data, estimated glyphosate doses to controls and low-, mid-, and high-dose groups were 0, 89, 362, and 940 mg/kg/day, respectively, for the males and 0, 113, 457, and 1,183 mg/kg/day, respectively, for the females.

Glyphosate treatment-related nonneoplastic effects included increased incidence of ocular effects (lens abnormalities), renal effects (increased specific gravity and decreased pH of urine) in high-dose (940 mg/kg/day) male rats, and significantly increased incidence of inflammation of gastric squamous mucosa in female rats at 457 and 1,183 mg/kg/day (incidences of 0/59, 3/60, 9/60 [p=0.0015], and 6/59 [p=0.014] among controls, low-, mid-, and high-dose groups, respectively; statistical significance determined using Fisher’s exact test). The high-dose (1,183 mg/kg/day) group of female rats exhibited as much as 13% lower mean body weight at treatment week 81. Relative liver weight was significantly increased in high-dose male rats evaluated at 12 months and terminal sacrifice (13–14% greater than controls); however, histopathologic examinations of liver sections revealed no evidence of significant treatment-related nonneoplastic effects.

Selection of the Point of Departure: A chronic-duration oral MRL can be derived for glyphosate based on incidences of female rats exhibiting gastric lesions in the 2-year dietary study of rats (EPA 1991a, 1991b). Incidences of female rats with gastric lesions were 0/59, 3/60, 9/60, and 6/59 for controls, low-, mid-, and high-dose groups, respectively. All dichotomous models in the Benchmark Dose Modeling Software (BMDS; Version 2.6) were fit to the incidence data for female rats exhibiting inflammation of gastric squamous mucosa. A benchmark response (BMR) of 10% extra risk was applied. None of the models produced adequate fit to the dataset, likely due to 33% lower incidence for the gastric lesion in the high-dose group compared to the mid-dose group. Therefore, a NOAEL/LOAEL approach was employed to derive a chronic-duration oral MRL for glyphosate. The point of departure is the NOAEL of 113 mg/kg/day for gastrointestinal lesions in the female rats of the 2-year dietary study (EPA 1991a, 1991b).

Uncertainty Factor: The NOAEL of 113 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

Per ATSDR guidance, MRLs are expressed to one significant figure, making the MRL 1 mg/kg/day.

The glyphosate-induced cytoplasmic changes in salivary glands of the chronically-treated rats were not considered for MRL derivation because the toxicological significance of the changes is uncertain. However, consideration of the NOAEL of 113 mg/kg/day (EPA 2015c) as a point of departure, application of a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) would also result in a chronic-duration oral MRL of 1 mg/kg/day.

Other Additional Studies or Pertinent Information: Glyphosate-induced gastrointestinal effects were observed in acute-duration oral studies of rats and rabbits (Adam et al. 1997; EPA 1992e, 2013c, 2017b), intermediate-duration oral studies of rats, mice, and rabbits (EPA 1992a, 1992f; NTP 1992), and chronic-duration oral studies of rats (EPA 1991a, 1991b, 2015c).

Agency Contact (Chemical Manager): Hana R. Pohl, M.D., Ph.D.