# 9 REFERENCES

* Not cited in text

ACGIH. 2016. Glutaraldehyde. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. 33.
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Ahishali E, Uygur-Bayramicli O, Dolapcioglu C, . 2009. Chemical colitis due to glutaraldehyde: Case series and review of the literature. Dig Dis Sci 54(12):2541–2545.19104938
AIHA. 2016. Current ERPG values (2016). AIHA guideline foundation. 2016 ERPG/WEEL handbook. American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2016%20ERPG%20Table.pdf. April 26, 2017.
Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology, 1987–2008, 2041.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
API. 2015. Hydraulic fracturing. Unlocking America’s natural gas resources. American Petroleum Institute. http://www.api.org/~/media/Files/Oil-and-Natural-Gas/Hydraulic-Fracturing-primer/Hydraulic-Fracturing-Primer-2015-highres.pdf. December 9, 2015.
Arntz D, Fischer A, Hopp M, . 2012. Acrolein and methacrolein. In: Ullmann’s encyclopedia of industrial chemistry. http://onlinelibrary.wiley.com/doi/10.1002/14356007.a01_149.pub2/abstract. April 6, 2014.
Atkinson R. 1989. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. J Phys Chem Ref Data. American Chemical Society.Vol. Monograph No. 1, 137.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
Azadi S, Klink KJ, Meade BJ. 2004. Divergent immunological responses following glutaraldehyde exposure. Toxicol Appl Pharmacol 197(1):1–8.15126069
Ballantyne B. 1995. Toxicology of glutaraldehyde. Review of studies and human health effects. Dow Chemical. ©The Dow Chemical Company. Do not reproduce without permission.
Ballantyne B, Jordan SL. 2001. Toxicological, medical and industrial hygiene aspects of glutaraldehyde with particular reference to its biocidal use in cold sterilization procedures. J Appl Toxicol 21(2):131–151.11288136
Ban-Weiss GA, McLaughlin JP, Harley RA, . 2008. Carbonyl and nitrogen dioxide emissions from gasoline- and diesel-powered motor vehicles. Environ Sci Technol 42:3944–3950.18589949
Bardazzi F, Melino M, Alagna G, . 1986. Glutaraldehyde dermatitis in nurses. Contact Dermatitis 14(5):319–320.
Baric I, Wagner L, Feyh P, . 1999. Sensitivity and specificity of free and total glutaric acid and 3-hydroxyglutaric acid measurements by stable-isotope dilution assays for the diagnosis of glutaric aciduria type I. J Inherit Metab Dis 22(8):867–881.10604139
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
BASF. 2013. [E-mail communication between SRC and BASF and unpublished studies related to Substance: 111-30-8_master_glutaral (IUC4 DSN 559)]. BASF - The Chemical Company. [unpublished study to be peer reviewed].
*BASF Corp. 1990a. Report No.: T-2198. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
*BASF Corp. 1990b. Report No.: T-2203. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
*BASF Corp. 1990c. Report No.: T-2248. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
*BASF Corp. 1990d. Report No.: T-2249. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
*BASF Corp. 1990e. Report No.: T-2287. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
BASF Corp. 1990f. Report No.: T-2295. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
BASF Corp. 1990g. Report No.: T-2296. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
*BASF Corp. 1990h. Report No.: T-2297. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
BASF Corp. 1990i. Report No.: T-2298. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
BASF Corp. 1990j. Report No.: T-2299. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
*BASF Corp. 1990k. Report No.: T-2303. Letter from BASF Corp to US EPA regarding submission of data on glutaraldehyde with attachments (English and German). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0526410-1.
BASF Corp. 1990l. Prenatal toxicity range-finding study in rats oral administration (drinking water) (February 02, 1990) (summary tables only) with cover letter dated 121691. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86920000653. OTS0535536.
BASF Corp. 1990m. Prenatal toxicity range-finding study in rabbits oral administration (gavage) (February 12, 1990) (summary tables only) with cover letter dated 121691. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535535.
BASF Corp. 1991a. Study of the prenatal toxicity of glutaraldehyde in rabbits after oral administration (gavage) (February 11, 1991) (Final report) with attachment and cover letter dated 121691. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86920000655. OTS0535538.
BASF Corp. 1991b. Study of the prenatal toxicity of glutaraldehyde in rats after oral administration (drinking water) (February 11, 1991) (Final report) with attachment and cover letter dated 121691. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86920000654. OTS0535537.
BASF Corp. 1991c. Letter submitting two enclosed prenatal toxicity oral administration range-finding studies (summary tables only) on pentanedial. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86920000656. OTS0535539.
Beauchamp RO, St Clair MB, Fennell TR, . 1992. A critical review of the toxicology of glutaraldehyde. Crit Rev Toxicol 22(3–4):143–174.1388704
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Birnbaum BA, Gordon RB, Jacobs JE. 1995. Glutaraldehyde colitis: Radiologic findings. Radiology 195(1):131–134.7892453
Cain WS, Schmidt R, Jalowayski AA. 2007. Odor and chemesthesis from exposures to glutaraldehyde vapor. Int Arch Occup Environ Health 80(8):721–731.17429675
Calder IM, Wright LP, Grimstone D. 1992. Glutaraldehyde allergy in endoscopy units. Lancet 339(8790):433.
Chan-Yeung M, McMurren T, Catonio-Begley F, . 1993. Occupational asthma in a technologist exposed to glutaraldehyde. J Allergy Clin Immunol 91(5):974–978.8491947
Clayton GD, Clayton FE, eds. 1989. Patty’s industrial hygiene and toxicology. Volume II, Part A. 4th ed. New York, NY: John Wiley & Sons, Inc., 288.
ChemIDplus. 2013. Glutaral. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://sis.nlm.nih.gov/chemical.html. March 20, 2013.
Chotani GK, Dodge TC, van Scheltinga AHT, . 2012. Enzymes, 2. Discovery and production. In: Ullmann’s encyclopedia of industrial chemistry. http://onlinelibrary.wiley.com/doi/10.1002/14356007.m09_m01/abstract. April 6, 2014.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cohen NL, Patton CM. 2006. Worker safety and glutaraldehyde in the gastrointestinal lab environment. Gastroenterol Nurs 29(2):100–104.16609303
Collins JJ, Burns C, Spencer P, . 2006. Respiratory cancer risks among workers with glutaraldehyde exposure. J Occup Environ Med 48(2):199–203.16474269
Confidential. 1987a. Cytogenicity study-bone marror in-vivo (final report; with attachment, cover sheet and letter dated 112691 (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0533792.
Confidential. 1987b. In vivo alkaline elution assay of WI226.01 for DNA cross links in rat testis with attachments, cover sheet and letter dated 112691 (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0533790.
Confidential. 1987c. In vivo alkaline elution assay of WI226.01 for DNA strand breaks in rat testis with attachments, cover sheet and letter dated 112691 (sanitized). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0533791.
*Confidential. 1991. Letter to USEPA regarding the enclosed evaluation summary on the lever modification of the Magnusson-Kligman guinea pig maximization test with glutaraldehyde (sanitized) w-attach. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS05333498.
Confidential. 2002. 24-Month drinking water study in Wistar rats with glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E/FYI. 8EHQ-0902-15204A. http://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearchView/A93991737DA6857485256D6E0055A03A. April 9, 2014.
Connaughton P. 1993. Occupational exposure to glutaraldehyde associated with tachycardia and palpitations. Med J Aust 159(8):567.
Corrado OJ, Osman J, Davies RJ. 1986. Asthma and rhinitis after exposure to glutaraldehyde in endoscopy units. Hum Toxicol 5:325–327.3095219
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Annu Rev Pharmacol Toxicol 44:87–110. 10.1146/annurev.pharmtox.44.101802.121424.14744240
Cullinan P, Hayes J, Cannon J, . 1992. Occupational asthma in radiographers. Lancet 340(Dec):1477.
Cusano F, Luciano S. 1993. Contact allergy to benzalkonium chloride and glutaraldehyde in a dental nurse. Contact Dermatitis 28(2):127–128.
Dailey JR, Parnes RE, Aminlari A. 1993. Glutaraldehyde keratopathy. Am J Ophthalmol 115(2):256–258.8430741
Descotes J. 1988. Identification of contact allergens: The mouse ear sensitization assay. J Toxicol Cutaneous Ocul Toxicol 7(4):263–272.
Di Prima T, De Pasquale R, Nigro M. 1988. Contact dermatitis from glutaraldehyde. Contact Dermatitis 19(3):219–220.
Di Stefano F, Siriruttanapruk S, McCoach J, . 1999. Glutaraldehyde: An occupational hazard in the hospital setting. Allergy 54(10):1105–1109.10536890
Dillon D, Combes R, Zeiger E. 1998. The effectiveness of Salmonella strains TA100, TA102 and TA104 for detecting mutagenicity of some aldehydes and peroxides. Mutagenesis 13(1):19–26.9491389
Di Prima T, De Pasquale R, Nigro M. 1988. Contact dermatitis from glutaraldehyde. Contact Dermatitis 19(3):219–220.
DOE. 2012. Protective action criteria (PAC). Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://orise.orau.gov/emi/scapa/chem-pacs-teels/default.htm. April 24, 2013.
Dolce P, Gourdeau M, April N, . 1995. Outbreak of glutaraldehyde-induced proctocolitis. Am J Infect Control 23(1):34–39.7762872
Durante L, Zulty JC, Israel E, . 1992. Investigation of an outbreak of bloody diarrhea: Association with endoscopic cleaning solution and demonstration of lesions in an animal model. Am J Med 92(5):476–480.1580294
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and Neurotoxicology. Neurotoxicology 33(3):586–604. 10.1016/j.neuro.2011.12.009.22198708
Ema M, Itami T, Kawasaki H. 1992. Teratological assessment of glutaraldehyde in rats by gastric intubation. Toxicol Lett 63(2):147–153.1455446
Emmanuel E, Hanna K, Bazin C, . 2005. Fate of glutaraldehyde in hospital wastewater and combined effects of glutaraldehyde and surfactants on aquatic organisms. Environ Int 31(3):399–406.15734192
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development. EPA600890066A. PB90238890.
EPA. 1991. Guidelines for developmental toxicity risk assessment. U.S. Environmental Protection Agency. EPA600FR91001. http://www2.epa.gov/sites/production/files/2014-11/documents/dev_tox.pdf. February 23, 2015.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. U.S. Environmental Protection Agency. EPA600890066F.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998a. Health effects test guidelines. OPPTS 870.7800. Immunotoxicity. U.S. Environmental Protection Agency. EPA712C98351. http://www.regulations.gov/contentStreamer?objectId=09000064809bc936&disposition=attachment&contentType=pdf. February 23, 2015.
EPA. 1998b. Health effects test guidelines. OPPTS 870.6200. Neurotoxicity screening. U.S. Environmental Protection Agency. EPA712C98238. http://www.regulations.gov/contentStreamer?objectId=09000064809bc92e&disposition=attachment&contentType=pdf. February 23, 2015.
EPA. 1998c. Health effects test guidelines. OPPTS 870.3700. Prenatal developmental toxicity study. U.S. Environmental Protection Agency. EPA712C98207. http://www.regulations.gov/contentStreamer?objectId=09000064809bc488&disposition=attachment&contentType=pdf. February 23, 2015.
EPA. 1998d. Health effects test guidelines. OPPTS 870.3800. Reproduction and fertility effects. U.S. Environmental Protection Agency. EPA712C98208. http://www.regulations.gov/contentStreamer?objectId=09000064809bc489&disposition=attachment&contentType=pdf. February 23, 2015.
EPA. 1998e. RCRA waste minimization PBT priority chemical list. U.S. Environmental Protection Agency. Fed Regist 63 FR 60332 http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2006. Glutaraldehyde: Report of the cancer assessment review committee. U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances.
EPA. 2007. Reregistration eligibility decision for glutaraldehyde. U.S. Environmental Protection Agency. EPA739R07006. http://www.epa.gov/oppsrrd1/REDs/glutaraldehyde-red.pdf. April 5, 2014.
EPA. 2009a. Drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 74 FR 51850:51850–51862. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. April 24, 2013.
EPA. 2009c. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. April 24, 2013.
EPA. 2012a. Designated as hazardous substances in accordance with section 311(b)(2)(a) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4 http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012b. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-S-12-001. http://water.epa.gov/drink/standards/hascience.cfm. April 24, 2013.
EPA. 2012c. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261, Appendix VIII http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012d. Reportable quantities of hazardous substances designated pursuant to section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3 http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012e. Standards for owners and operators of hazardous waste TSD facilities. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 264, Appendix IX http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012f. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4 http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012g. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012h. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65 http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012i. Toxic Substances Control Act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30 http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2012j. Toxic Substances Control Act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 716.120 http://www.gpo.gov/fdsys. April 24, 2013.
EPA. 2013a. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/. April 24, 2013.
EPA. 2013b. Acute exposure guideline levels (AEGLs). Second AEGL chemical priority list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/aegl/pubs/priority_2.htm. April 24, 2013.
EPA. 2013c. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code 42 USC 7412 http://www.epa.gov/ttn/atw/orig189.html. April 24, 2013.
EPA. 2013d. Inert ingredients permitted for use in nonfood pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=124:1. April 24, 2013.
EPA. 2013e. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/mtl.html. April 24, 2013.
EPA. 2013f. National ambient air quality standards (NAAQS). Washington, DC: Office of Air and Radiation, U.S. Environmental Protection Agency. http://www.epa.gov/air/criteria.html. April 24, 2013.
EPA. 2013g. Glutaraldehyde. Inert finder. U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=INERTFINDER:3:0::NO::P3_ID:7419. March 20, 2013.
FDA. 2007. Redbook 2000. Guidance for industry and other stakeholders toxicological principles for the safety assessment of food ingredients U.S. Food and Drug Administration. http://www.fda.gov/downloads/Food/GuidanceRegulation/UCM222779.pdf. February 23, 2015.
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. April 24, 2013.
FDA. 2015. FDA-cleared sterilants and high level disinfectants with general claims for processing reusable medical and dental devices-March 2015. Food and Drug Administration. https://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/ReprocessingofReusableMedicalDevices/ucm437347.htm. April 17, 2017.
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Fowler JF. 1989. Allergic contact dermatitis from glutaraldehyde exposure. J Occup Med 31(10):852–853.2514257
Frantz SW, Beskitt JL, Tallant MJ, . 1993. Glutaraldehyde: Species comparisons of in vitro skin penetration. J Toxicol Cutaneous Ocul Toxicol 12(4):349–361.
Fukunaga K, Khatibi A. 2000. Glutaraldehyde colitis: A complication of screening flexible sigmoidoscopy in the primary care setting. Ann Intern Med 133(4):315.10929189
Galloway SM, Bloom AD, Resnick M, . 1985. Development of a standard protocol for in vitro cytogenetic testing with Chinese hamster ovary cells: Comparison of results for 22 compounds in two laboratories. Environ Mutagen 7:1–51.
Gannon PF, Bright P, Campbell M, . 1995. Occupational asthma due to glutaraldehyde and formaldehyde in endoscopy and x ray departments. Thorax 50(2):156–159.7701454
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Gross EA, Mellick PW, Kari FW, . 1994. Histopathology and cell replication responses in the respiratory tract of rats and mice exposed by inhalation to glutaraldehyde for up to 13 weeks. Fundam Appl Toxicol 23(3):348–362.7835535
Guthua SW, Macigo FG, Mwaniki DL, . 2001. Symptoms in health personnel exposed to disinfectants. East Afr Med J 78(3):157–160.12002058
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
Halatek T, Opalska B, Swiercz R, . 2003. Glutaraldehyde inhalation exposure of rats: effects on lung morphology, Clara-cell protein, and hyaluronic acid levels in BAL. Inhal Toxicol 15(1):85–97.12476362
Hamann CP, Rodgers PA, Sullivan K. 2003. Allergic contact dermatitis in dental professionals: effective diagnosis and treatment. J Am Dent Assoc 134(2):185–194.12636122
Hansen KS. 1983a. Glutaraldehyde occupational dermatitis. Contact Dermatitis 9(1):81–82.6220863
Hansen KS. 1983b. Occupational dermatoses in hospital cleaning women. Contact Dermatitis 9(5):343–351.6226477
Hanson JM, Plusa SM, Bennett MK, . 1998. Glutaraldehyde as a possible cause of diarrhoea after sigmoidoscopy. Br J Surg 85(10):1385–1387.9782020
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):3–142.
HazDat. 2007. Glutaraldehyde. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Hemminki K, Falck K, Vainio H. 1980. Comparison of alkylation rates and mutagenicity of directly acting industrial and laboratory chemicals. Arch Toxicol 46:277–285.7236006
Hemminki K, Kyyronen P, Lindbohm ML. 1985. Spontaneous abortions and malformations in the offspring of nurses exposed to anaesthetic gases, cytostatic drugs, and other potential hazards in hospitals, based on registered information of outcome. J Epidemiol Community Health 39(2):141–147.3925060
Hemminki K, Mutanen P, Saloniemi I, . 1982. Spontaneous abortions in hospital staff engaged in sterilising instruments with chemical agents. Br Med J (Clin Res Ed) 285(6353):1461–1463.
Hilton J, Dearman RJ, Harvey P, . 1998. Estimation of relative skin sensitizing potency using the local lymph node assay: A comparison of formaldehyde with glutaraldehyde. Am J Contact Dermat 9(1):29–33.9471984
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoechst Celanese Corp. 1981. An acute inhalation toxicity study of C-204 in the rat with glutaraldehyde (project report) with cover letter dated 112791. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86-920000304. OTS0533523.
Hoffman RS, Howland MA, Lewin NA, . 2015. Glutaraldehyde. In: Goldfrank’s toxicologic emergencies. New York, NY: McGraw-Hill Education, 1301–1302.
HSDB. 2011. Glutaraldehyde. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. April 6, 2014.
IARC. 2013. Agents classified by the IARC monographs. Volumes 1-107. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. April 24, 2013.
IPCS. 1998. Glutaraldehyde. OECD Screening information dataset (SIDS) high production volume chemicals. International Programme on Chemical Safety. http://www.inchem.org/documents/sids/sids/111308.pdf. April 5, 2014.
IPCS. 2000. Glutaraldehyde. International Chemical Safety Cards (ICSCs). International Programme on Chemical Safety. http://www.inchem.org/documents/icsc/icsc/eics0158.htm. March 20, 2013.
IRIS. 2013. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. April 24, 2013.
Jachuck SJ, Bound CL, Steel J, . 1989. Occupational hazard in hospital staff exposed to 2 per cent glutaraldehyde in an endoscopy unit. J Soc Occup Med 39(2):69–71.2525652
Jolibois B, Guerbet M, Vassal S. 2002. Glutaraldehyde in hospital wastewater. Arch Environ Contam Toxicol 42(2):137–144.11815804
Jordan WJ, Dahl MV, Albert HL. 1972. Contact dermatitis from glutaraldehyde. Arch Dermatol 105(1):94–95.4257913
Jung R, Engelhart G, Herbolt B, . 1992. Collaborative study of mutagenicity with Salmonella typhimurium TA102. Mutat Res 278:265–270.1373863
Kamber M, Flückiger-Isler S, Engelhardt G, . 2009. Comparison of the Ames II and traditional Ames test responses with respect to mutagenicity, strain specificities, need for metabolism and correlation with rodent carcinogenicity. Mutagenesis 24(4):359–366.19447896
Kanerva L, Miettinen P, Alanko K, . 2000. Occupational allergic contact dermatitis from glyoxal, glutaraldehyde and neomycin sulfate in a dental nurse. Contact Dermatitis 42(2):116–117.10703647
Katagiri H, Yamamoto T, Uchimura A, . 2011. The alterations in neurotransmitters and their metabolites in discrete brain regions in the rats after inhalation of disinfectant, glutaraldehyde or ortho-phthalaldehyde for 4 weeks. Ind Health 49(3):328–337.21372440
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology-drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167. 10.1056/NEJMra035092.13679531
Kiec-Swierczynska M, Krecisz B. 2001. Occupational allergic contact dermatitis in hairdressers due to glutaraldehyde. Contact Dermatitis 44(3):185–186.
Kieć-Świerczyńska M, Krecisz B, Pałczyński C, . 2001. Allergic contact dermatitis from disinfectants in farmers. Contact Dermatitis 45(3):168–169.11553146
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kucenic MJ, Belsito DV. 2002. Occupational allergic contact dermatitis is more prevalent than irritant contact dermatitis: A 5-year study. J Am Acad Dermatol 46(5):695–699.12004309
Kuchenmeister F, Schmezer P, Engelhardt G. 1998. Genotoxic bifunctional aldehydes produce specific images in the comet assay. Mutat Res 419:69–78.9804897
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leikin JB, Paloucek FP. 2008. Glutaraldehyde. In: Poisoning and toxicology handbook. 4th ed. Boca Raton, FL: CRC Press, 800.
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Leung HW. 2001. Aerobic and anaerobic metabolism of glutaraldehyde in a river water-sediment system. Arch Environ Contam Toxicol 41(3):267–273.11503062
Levin DE, Hollstein M, Christman MF, . 1982. A new Salmonella tester strain (TA102) with A-T base pairs at the site of mutation detects oxidative mutagens. Proc Natl Acad Sci USA 79:7445–7449.6760198
Lewis RJ. 2007. Glutaraldehyde. In: Hawley’s condensed chemical dictionary. 15th ed. Hoboken, NJ: John Wiley & Sons, Inc., 610.
Lindahl R, Levin JO. 1995. Laboratory validation of a diffusive sampler for the determination of glutaraldehyde in air. J Chromatogr A 710(1):175–180.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Maibach H. 1975. Glutaraldehyde: Cross-reactions to formaldehyde? Contact Dermatitis 1(5):326–327.828571
Marnett LJ, Hurd HK, Hollstein MC, . 1985. Naturally occurring carbonyl compounds are mutagens in Salmonella tester strain TA104. Mutat Res 148:25–34.3881660
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McCurdy R. 2011. EPA hydraulic fracturing workshop 1. February 24–25, 2011. Chesapeake Energy. http://www.epa.gov/sites/production/files/documents/highratehfinnon-marcellusunconventionalshale.pdf. December 9, 2015.
McEntee T. 2000. Industrial antimicrobial agents. In: Kirk-Othmer encyclopedia of chemical technology. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.0914042113030514.a01/abstract. April 6, 2014.
McGinley HR. 2012. Glutaraldehyde uses and counterfeits. Water Technol 35(9):30–33.
McGregor DB, Brown A, Cattanach P, . 1988. Responses of the L5178Y tk-positive/tk-negative mouse lymphoma cell forward mutation assay II: 18 coded chemicals. Environ Mol Mutagen 11(1):91–118.3338442
Mckelvey JA, Garman RH, Anuszkiewicz CM, . 1992. Percutaneous pharmacokinetics and material balance studies with glutaraldehyde. Cutan Ocul Toxicol 11(4):341–367.
Mirsalis JC, Tyson CK, Steinmetz KL, . 1989. Measurement of unscheduled DNA synthesis and S-phase synthesis in rodent hepatocytes following in vivo treatment: Testing of 24 compounds. Environ Mol Mutagen 14(3):155–164.2792091
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Myers DR, Pashley DH, Lake FT, . 1986. Systemic absorption of 14C-glutaraldehyde from glutaraldehyde-treated pulpotomy sites. Pediatr Dent 8(3):134–138.3090522
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Neeper-Bradley TL, Ballantyne B. 2000. Two-generation reproduction study by dosing with glutaraldehyde in the drinking water of CD rats. J Toxicol Environ Health A 60:107–129.
Nethercott JR, Holness DL, Page E. 1988. Occupational contact dermatitis due to glutaraldehyde in health care workers. Contact Dermatitis 18(4):193–196.2967745
Nettis E, Colanardi MC, Soccio AL, . 2002. Occupational irritant and allergic contact dermatitis among healthcare workers. Contact Dermatitis 46:101–107.11918604
NICNAS. 1994. Priority existing chemical Number 3. Glutaraldehyde. Full public report. Canberra, Australia: National Industrial Chemicals Notification and Assessment Scheme. Australian Government Publishing Service.
NIOSH. 1987a. Glutaraldehyde at Montgomery Hospital, Norristown, Pennsylvania Health Hazard Evaluation (HHE). Cincinnati, OH: National Institute for Occupational Safety and Health. HETA862261769. http://www.cdc.gov/niosh/hhe/reports/pdfs/1986-0226-1769.pdf. April 10, 2014.
NIOSH. 1987b. Health Hazard Evaluation Report HETA 85-257-1791, Mercy Medical Center, Denver, Colorado. Cincinnati, OH: National Institute for Occupational Safety and Health. HETA852571791.
NIOSH. 2000. Glutaraldehyde. International Chemical Safety Cards. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/ipcsneng/neng0158.html. April 6, 2014
NIOSH. 2016. Glutaraldehyde. NIOSH pocket guide to chemical hazards. Appendix C-supplementary exposure limits. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0301.html. April 24, 2017.
Norbäck D. 1988. Skin and respiratory symptoms from exposure to alkaline glutaraldehyde in medical services. Scand J Work Environ Health 14(6):366–371.2975045
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press. PB93216091.
NTP. 1993. NTP Technical report on toxicity studies of glutaraldehyde (CAS No. 111-30-8) administered by inhalation to F344/N rats and B6C3F1 mice. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services. NIH Publication 93-3348, Number 25.
NTP. 1999. NTP Technical Report on the toxicology and carcinogenesis studies of glutaraldehyde in F344/N rats and B6C3F1 mice. Inhalation studies. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services. NIH Publication No. 99-3980. NTP TR490.
NTP. 2013a. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments—February 2013. National Toxicology Program. http://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. October 15, 2014.
NTP. 2013b. Appendix 2: Guidance for assessing risk of bias in the protocol for evaluating the evidence for an association between PFOA and PFOS exposure and immunotoxicity. In: Systematic review to evaluate the evidence for an association between perfluorooctanoic acid (PFOA) or perfluorooctane sulfonate (PFOS) exposure and immunotoxicity. National Toxicology Program. http://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/appendix_2_pfoa_pfos_riskofbias.pdf. February 26, 2015.
NTP. 2014. Report on carcinogens. Thirteenth edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/content/listed_substances_508.pdf. November 30, 2015.
Nunoshiba T, Hashimoto M, Nishioka H. 1991. Cross-adaptive response in Escherichia coli caused by pretreatment with H2O2 against formaldehyde and other aldehyde compounds. Mutat Res 255(3):265–271.1719398
OECD. 1983. Test No. 415: One-generation reproduction toxicity study. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-415-one-generation-reproduction-toxicity-study_9789264070844-en. February 23, 2015.
OECD. 1992. Test No. 406: Skin sensitisation. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-406-skin-sensitisation_9789264070660-en. February 23, 2015.
OECD. 1998. Test No. 408: Repeated dose 90-day oral toxicity study in rodents. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-408-repeated-dose-90-day-oral-toxicity-study-in-rodents_9789264070707-en. February 23, 2015.
OECD. 2001a. Test No. 414: Prenatal development toxicity study. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-414-prenatal-development-toxicity-study_9789264070820-en. February 23, 2015.
OECD. 2001b. Test No. 416: Two-generation reproduction toxicity. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-416-two-generation-reproduction-toxicity_9789264070868-en. February 23, 2015.
OECD. 2009a. Test No. 412: Subacute inhalation toxicity: 28-Day study. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-412-subacute-inhalation-toxicity-28-day-study_9789264070783-en. February 23, 2015.
OECD. 2009b. Test No. 451: Carcinogenicity studies. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-451-carcinogenicity-studies_9789264071186-en. February 23, 2015.
OECD. 2009c. Test No. 452: Chronic toxicity studies. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-452-chronic-toxicity-studies_9789264071209-en. February 23, 2015.
OECD. 2009d. Test No. 453: Combined chronic toxicity/carcinogenicity studies. OECD guidelines for the testing of chemicals, section 4: Health effects. OECD ilibrary. Organisation for Economic Co-operation and Development. http://www.oecd-ilibrary.org/environment/test-no-453-combined-chronic-toxicity-carcinogenicity-studies_9789264071223-en. February 23, 2015.
Ong TH, Tan KL, Lee HS, . 2004. A case report of occupational asthma due to glutaraldehyde exposure. Ann Acad Med Singapore 33(2):275–278.15098649
OSHA. 2013a. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000, Table Z-1. http://www.osha.gov/law-regs.html. April 24, 2013.
OSHA. 2013b. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.119, Appendix A. http://www.osha.gov/law-regs.html. April 24, 2013.
OSHA. 2017. Healthcare wide hazards. Gluteraldehyde. Occupational Safety and Health Administration. https://www.osha.gov/SLTC/etools/hospital/hazards/glutaraldehyde/glut.html. April 26, 2017.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Palczynski C, Walusiak J, Krakowiak A, . 2005. Glutaraldehyde-induced occupational asthma: BALF components and BALF and serum Clara cell protein (CC16) changes due to specific inhalatory provocation test. Occup Med (Lond) 55(7):572–574.16251377
Palczynski C, Walusiak J, Ruta U, . 2001. Occupational asthma and rhinitis due to glutaraldehyde: Changes in nasal lavage fluid after specific inhalatory challenge test. Allergy 56(12):1186–1191.11736748
Perera PM, Kularathne K, Gawarammana IB. 2008. Laryngeal edema and metabolic acidosis after Omnicide ingestion. Clin Toxicol (Phila) 46(9):858–860.18608252
Peters K, Richards FM. 1977. Chemical cross-linking: Reagents and problems in studies of membrane structure. Annu Rev Biochem 46:523–551.409338
Pisaniello DL, Gun RT, Tkaczuk MN, . 1997. Glutaraldehyde exposures and symptoms among endoscopy nurses in South Australia. Appl Occup Environ Hyg 12(3):171–177.
Potter DW, Wederbrand KS. 1995. Total IgE antibody production in BALB/c mice after dermal exposure to chemicals. Fundam Appl Toxicol 26(1):127–135.7657056
Quirce S, Gomez M, Bombin C, . 1999. Glutaraldehyde-induced asthma. Allergy 54(10):1121–1122.10536899
Ranly DM, Horn D. 1990. Distribution, metabolism, and excretion of [14C] glutaraldehyde. J Endod 16(3):135–139.2117632
Ranly DM, Amstutz L, Horn D. 1990. Subcellular localization of glutaraldehyde. Endod Dent Traumatol 6(6):251–254.2128827
Ravis SM, Shaffer MP, Shaffer CL, . 2003. Glutaraldehyde-induced and formaldehyde-induced allergic contact dermatitis among dental hygienists and assistants. J Am Dent Assoc 134(8):1072–1078.12956347
Reifenrath WG, Prystowsky SD, Nonomura JH, . 1985. Topical glutaraldehyde-percutaneous penetration and skin irritation. Arch Dermatol Res 277(3):242–244.3925896
RePORTER. 2014. Glutaraldehyde. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. April 7, 2014.
Rietz B. 1985. Determination of three aldehydes in the air of working environments. Anal Lett 18(19):2369–2379.
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rozen P, Somjen GJ, Baratz M, . 1994. Endoscope-induced colitis: Description, probable cause by glutaraldehyde, and prevention. Gastrointest Endosc 40(5):547–553.7988816
Ruiz-Rubion M, Alejandre-Duran E, Pueyo C. 1985. Oxidative mutagens specific for A-T base pairs induce forward mutations to L-arabinose resistance in Salmonella typhimurium. Mutat Res 147:153–163.3894949
Sakagami Y, Yamazaki H, Ogasawara N, . 1988b. The evaluation of genotoxic activities of disinfectants and their metabolites by umu test. Mutat Res 209:155–160.3143068
Sakagami Y, Yamasaki K, Yokoyama H, . 1988a. DNA repair test of disinfectants by liquid rec-assay. Mutat Res 193(1):21–30.3122031
Sanderson KV, Cronin E. 1968. Glutaraldehyde and contact dermatitis. Br Med J 3(5621):802.5676718
Sano LL, Krueger AM, Landrum PF. 2005. Chronic toxicity of glutaraldehyde: Differential sensitivity of three freshwater organisms. Aquat Toxicol 71(3):283–296.15670634
Sasaki Y, Endo R. 1978. Mutagenicity of aldehydes in Salmonella. Mutat Res 54(2):251–252.
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286. 10.1016/j.tins.2008.03.003.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Frontiers in pharmacology 3:Article 46. 10.3389/fphar.2012.00046.
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Sekine Y, Oikawa D, Saitoh K, . 2005. Evaluation of passive sampler for measurement of glutaraldehyde in occupational indoor air. J Health Sci 51(6):629–635.
Shaffer MP, Belsito DV. 2000. Allergic contact dermatitis from glutaraldehyde in health-care workers. Contact Dermatitis 43(3):150–156.10985631
Shigematsu Y, Hata I, Tanaka Y, . 2005. Stable-isotope dilution gas chromatography-mass spectrometric measurement of 3-hydroxyglutaric acid, glutaric acid and related metabolites in body fluids of patients with glutaric aciduria type 1 found in newborn screening. J Chromatogr B Analyt Technol Biomed Life Sci 823(1):7–12.
Shih HY, Wu DC, Huang WT, . 2011. Glutaraldehyde-induced colitis: Case reports and literature review. Kaohsiung J Med Sci 27(12):577–580.22208542
Siebert J, Harke HP. 2012. Disinfectants. In: Ullmann’s encyclopedia of industrial chemistry. http://onlinelibrary.wiley.com/doi/10.1002/14356007.a08_551.pub2/abstract. April 6, 2014.
Simonenko V, Syuch N, Prostakishin G, . 2009. Unfavorable outcome in severe systemic toxicity after concentrated glutaraldehyde ingestion. Toxicology Letters (Shannon) 189(Sp. Iss. SI):S253.
Slesinski RS, Hengler WC, Guzzie PJ, . 1983. Mutagenicity evaluation of glutaraldehyde in a battery of in vitro bacterial and mammalian test systems. Food Chem Toxicol 21(5):621–629.6418627
Smith DR, Wang R. 2006. Glutaraldehyde exposure and its occupational impact in the health care environment. Environ Health Prev Med 11:3–10.21432369
Speit G, Neuss S, Schutz P, . 2008. The genotoxic potential of glutaraldehyde in mammalian cells in vitro in comparison with formaldehyde. Mutat Res 649(1–2):146–154.18006368
St Clair MB, Bermudez E, Gross EA, . 1991. Evaluation of the genotoxic potential of glutaraldehyde. Environ Mol Mutagen 18(2):113–119.1908774
Stein BL, Lamoureux E, Miller M, . 2001. Glutaraldehyde-induced colitis. Can J Surg 44(2):113–116.11308232
Stern ML, Holsapple MP, Ja, . 1989. Contact hypersensitivity response to glutaraldehyde in Guinea pigs and mice. Toxicol Ind Health 5(1):31–43.
Stingeni L, Lapomarda V, Lisi P. 1995. Occupational hand dermatitis in hospital environments. Contact Dermatitis 33(3):172–176.8565458
Stromberg PC, Vogtsberger LM, Marsh LR, . 1983. Pathology of the mononuclear cell leukemia of Fischer rats. II. Hematology. Vet Pathol 20:709–717.6649339
Tam M, Freeman S. 1989. Occupational allergic contact dermatitis due to glutaraldehyde: a study of six cases due to Wavicide and Aldecyde. J Occup Health Safety—Aust NZ 5:487–491.
Teta MJ, Avashia BH, Cawley TJ, . 1995. Absences of sensitizations and cancer increases among glutaraldehyde workers. Toxic Subst Mech 14:293–305.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
*Thomas S, Russell AD. 1974. Temperature-induced changes in the sporicidal activity and chemical properties of glutaraldehyde. Appl Microbiol 28(3):331–335.4213869
Trigg C, Heap D, Herdman M, . 1992. A radiographer’s asthma. Respir Med 86(2):167–169.1615185
Tsai CC, Huang RN, Sung HW, . 2000. In vitro evaluation of the genotoxicity of a naturally occurring crosslinking agent (genipin) for biologic tissue fixation. J Biomed Mater Res 52(1):58–65.10906675
Uhr H, Mielke B, Exner O, . 2013. Biocides. In: Ullmann’s encyclopedia of industrial chemistry. http://onlinelibrary.wiley.com/doi/10.1002/14356007.a16_563.pub2/abstract. April 9, 2014.
Unal M, Yucel I, Akar Y, . 2006. Outbreak of toxic anterior segment syndrome associated with glutaraldehyde after cataract surgery. J Cataract Refract Surg 32(10):1696–1701.17010870
*Union Carbide. 1991. Letter submitting multiple enclosed studies on multiple chemicals with attachment. Union Carbide Chemicals and Plastics Company Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991a. Report 17-61. Range finding tests on glutaraldehyde (25% aqueous). Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991b. Report 24-80. Progress report for the month ended August 31, 1961. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991c. Special report 37-54. Miscellaneous toxicity studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991d. Special report 38-111. Glutaraldehyde. Results of feeding in the diets of rats for 7 days. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991e. Special report 38-146. UCARCIDE sanitizer 401 and 402 (sanitizer 402 is one part sanitizer 401; 9 parts water) range finding toxicity studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991f. Report 39-5. Glutaraldehyde. Results of inclusion in the drinking water of rats for 4 days. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991g. Special report 39-40. Miscellaneous toxicity studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991h. Project report 41-77. Miscellaneous toxicity studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991i. Project report 44-7. UCARCIDE antimicrobial 125LT. D.O.T. skin irritation study. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991j. Project report 44-15. UCARCIDE 250 antimicrobial. Department of Transportation (D.O.T.) skin corrosivity tests. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991k. Project report 44-65. Glutaraldehyde dilutions. Percutaneous toxicity and eye irritation studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991l. Project report 45-124. Glutaraldehyde dilutions. Acute peroral toxicity studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991m. Project report 47-33. Glutaraldehyde dilutions. Primary skin and eye irritancy studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991n. Project report 47-166. Aqucar 514 water treatment microbiocide. Acute toxicity and irritancy study. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991o. Project report 47-190. Glutaraldehyde. Two-week inclusion in drinking water of rats. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991p. Project report 48-3. Aqucar 514. Acute inhalation toxicity study. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991q. Project report 48-51. Glutaraldehyde dilutions (45%, 15% and 10%). Acute percutaneous studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991r. Project report 48-107. Addendum to glutaraldehyde: Ninety-day inclusion in drinking water. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991s. Project report 49-97. UCARCIDE instrument sterilant 602. Acute peroral toxicity study in the rat. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991t. Project report 50-92. UCARCIDE 145LT. Acute peroral toxicity study in the rat. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991u. Report 50-105. UCARCIDE antimicrobial 145LT. Acute percutaneous and inhalation toxicity studies. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991v. Laboratory project ID 51-27. Glutaraldehyde: Fourteen-day drinking water toxicity study in mice. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991w. Laboratory project ID 52-1. Glutaraldehyde: Ninety-day drinking water toxicity study in mice. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991x. Laboratory project ID 53-8. UCARCIDE antimicrobial 250. Acute vapor inhalation toxicity test in rats. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991y. Project report 44-107. Evaluation of subchronic dermal toxicity of glutaraldehyde in mice. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991z. Laboratory project ID 50-101. UCARCIDE antimicrobial 145LT. Acute peroral toxicity study in the rat. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991aa. Laboratory project ID 50-102. UCARCIDE antimicrobial 145LT. Acute percutaneous toxicity study in the rabbit. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
*Union Carbide Chem & Plas Co. 1991bb. Laboratory project ID 50-103. UCARCIDE antimicrobial 145LT primary skin irritancy study in the rabbit. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991cc. Laboratory project ID 50-104. UCARCIDE antimicrobial 145LT primary eye irritancy study in the rabbit. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991dd. Project report 52-10. Glutaraldehyde: 2-Week dosing feasibility study in dogs with administration via the drinking water or by gavage. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991ee. Project report 52-93. Glutaraldehyde: 13-Week toxicity study in dogs with administration via the drinking water. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991ff. Project report 43-130. A preliminary material balance study of glutaraldehyde in the rats. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991gg. Project report 43-16. Glutaraldehyde (50%). In vitro mutagenesis studies: 3-Test battery. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991hh. Project report 44-67. Glutaraldehyde (50%). In vitro mutagenesis studies: CHO mutation test. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991ii. Project report 44-131. Glutaraldehyde. Salmonella/microsome (Ames). Bacterial mutagenicity assay. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1991jj. Laboratory project ID 54-101. UCARCIDE antimicrobial 250 (Glutaraldehyde, 50% aqueous solution): In vitro chromosomal aberrations assay in Chinese hamster ovary cells. Letter submitting multiple enclosed studies on multiple chemicals with attachments. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0535072.
Union Carbide Chem & Plas Co. 1992. UCARCIDE antimicrobial 250: Acute peroral toxicity study in the rat (final report) with cover letter dated 011692. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86920000753. OTS0535081.
Union Carbide Corp. 1966. Repeated insult patch test of glutaraldehyde, 5% solution, with cover letter dated 11/14/95. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0558276.
Union Carbide Corp. 1976. Human sensory irritation threshold of glutaraldehyde vapor, with cover letter dated 4/11/96. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86960000358. OTS0558406.
Union Carbide Corp. 1980. Repeated insult patch test of glutaraldehyde (0.1%, 0.2%, 0.5% solution) with cover letter dated 11/14/95. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86960000134. OTS0558274.
*Union Carbide Corp. 1991. Letter submitting an ocular and respiratory irritation study for two glutaraldehyde containing aqueous mixtures. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA86-930000216. OTS0537659.
Union Carbide Corp. 1992a. Report 27-137. Range finding tests on glutaraldehyde, 45% aqueous. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
Union Carbide Corp. 1992b. Project report 40-50. Glutaraldehyde, 50% aqueous solution. Range finding toxicity studies. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
Union Carbide Corp. 1992c. Project report 40-120. Glutaraldehyde 25% aqueous. Range finding toxicity studies. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
Union Carbide Corp. 1992d. Project report 46-63. Glutaraldehyde vapor nine-day inhalation study on rats. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
Union Carbide Corp. 1992e. Project report 46-95. Glutaraldehyde vapor nine-day inhalation study on rats. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
Union Carbide Corp. 1992f. Project report 46-101. Glutaraldehyde vapor subchronic inhalation study on rats. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
*Union Carbide Corp. 1992g. Project report 47-21. Glutaraldehyde. Acute inhalation toxicity with chamber analysis. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP.
Union Carbide Corp. 1992h. Project report 51-14. 50% Aqueous glutaraldehyde samples (UGARCID 250 and BASF 50% glutaraldehyde. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
Union Carbide Corp. 1992i. Project report 51-37. Glutaraldehyde dilutions: Acute peroral toxicity studies in the mouse. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
Union Carbide Corp. 1992j. Project report 52-116. 50% Glutaraldehyde (UCARCIDE 250) primary skin irritancy studies in the rabbit. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
*Union Carbide Corp. 1992k. Project report 44-97. Glutaraldehyde. Six-hour static LT50 on rats. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
Union Carbide Corp. 1992l. Report 44-96. Glutaraldehyde four-hour LC50 inhalation study on rats. Initial submission: Letter submitting twelve enclosed toxicology studies on glutaraldehyde. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8ECP. OTS0536179.
*Union Carbide Corp. 1996. Human sensory irritation threshold of glutaraldehyde vapor, with cover letter dated 04/11/1996. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0558406.
U.S. Coast Guard. 2004. Evaluation of biocides for potential treatment of ballast water. Washington, DC: United States Coast Guard. ADA429663.
van Birgelen AP, Chou BJ, Renne RA, . 2000. Effects of glutaraldehyde in a 2-year inhalation study in rats and mice. Toxicol Sci 55(1):195–205.10788574
van Miller JP, Hermansky SJ, Losco PE, . 2002. Chronic toxicity and oncogenicity study with glutaraldehyde dosed in the drinking water of Fischer 344 rats. Toxicology 175(1–3):177–189.12049846
van Triel JJ, van Bree BW, Roberts DW, . 2011. The respiratory allergen glutaraldehyde in the local lymph node assay: Sensitization by skin exposure, but not by inhalation. Toxicology 279(1–3):115–122.20933045
Varpela E, Otterstrom S, Hackman R. 1971. Liberation of alkalinized glutaraldehyde by respirators after cold sterilization. Acta Anaesthesiol Scand 15(4):291–298.5292969
Vergnes JS, Ballantyne B. 2002. Genetic toxicology studies with glutaraldehyde. J Appl Toxicol 22(1):45–60.11807929
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vock EH, Lutz WK, Ilinskaya O, . 1999. Discrimination between genotoxicity and cytotoxicity for the induction of DNA double-strand breaks in cells treated with aldehydes and diepoxides. Mutat Res 441(1):85–93.10224325
von der Hude W, Behm C, Gurtler R, . 1988. Evaluation of the SOS chromotest. Mutat Res 203:81–94.3280989
Vyas A, Pickering CA, Oldham LA, . 2000. Survey of symptoms, respiratory function, and immunology and their relation to glutaraldehyde and other occupational exposures among endoscopy nursing staff. Occup Environ Med 57(11):752–759.11024199
Waldron HA. 1992. Glutaraldehyde allergy in hospital workers. Lancet 339(8797):880.
Watanabe K, Sakamoto K, Sasaki T. 1998. Comparisons on chemically-induced mutation among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101. Mutat Res 412:17–31.9508361
Waters A, Beach J, Abramson M. 2003. Symptoms and lung function in health care personnel exposed to glutaraldehyde. Am J Ind Med 43(2):196–203.12541275
Wellons SL, Trawick EG, Stowers MF, . 1998. Laboratory and hospital evaluation of four personal monitoring methods for glutaraldehyde in ambient air. Am Ind Hyg Assoc J 59(2):96–103.9487663
Werley MS, Ballantyne B, Neptun DA, . 1996. Four-week repeated skin contact study with glutaraldehyde in rats. J Toxicol Cutaneous Ocul Toxicol 15(2):179–193.
Werley MS, Burleigh-Flayer HD, Ballantyne B. 1995. Respiratory peripheral sensory irritation and hypersensitivity studies with glutaraldehyde vapor. Toxicol Ind Health 11(5):489–501.8677514
West AB, Kuan SF, Bennick M, . 1995. Glutaraldehyde colitis following endoscopy: clinical and pathological features and investigation of an outbreak. Gastroenterology 108(4):1250–1255.7698592
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 24, 2013.
WHO. 2011. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/publications/2011/dwq_guidelines/en/index.html. April 24, 2013.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Wilcox P, Naidoo A, Wedd DJ, . 1990. Comparison of Salmonella typhimurium TA102 with Escherichia coli WP2 tester strains. Mutagenesis 5(3):285–291.2200948
Winslow RM. 2003. Blood substitutes. In: Kirk-Othmer encyclopedia of chemical technology. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.0212151523091419.a01.pub2/abstract. April 6, 2014.
Wu A, Schmalz J, Bennett W. 1994. Identification of UrinAid-adulterated urine specimens by fluorometric analysis. Clin Chem 40(5):845–846.8174265
Wulff K, Henniger G. 2012. Enzymes, 7. Enzymes in analyzsis. In: Ullmann’s encyclopedia of industrial chemistry. http://onlinelibrary.wiley.com/doi/10.1002/14356007.m09_m06/abstract. April 6, 2014.
Yamaguchi F, Tsutsui T. 2003. Cell-transforming activity of fourteen chemical agents used in dental practice in Syrian hamster embryo cells. J Pharmacol Sci 93:497–500.14737023
Yoon JS, Mason JM, Valencia R, . 1985. Chemical mutagenesis testing in drosophila. IV. Results of 45 coded compounds tested for the national toxicology program. Environ Mutagen 7:349–367.3930235
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372
Zeiger E, Gollapudi B, Spencer P. 2005. Genetic toxicity and carcinogenicity studies of glutaraldehyde-a review. Mutat Res 589(2):136–151.15795166
Zimmering S, Mason JM, Valencia R. 1989. Chemical mutagenesis testing in Drosophila: VII. Results of 22 coded compounds tested in larval feeding experiments. Environ Mol Mutagen 14(4):245–251.2583131
Zissu D, Bonnet P, Binet S. 1998. Histopathological study in B6C3F1 mice chronically exposed by inhalation to glutaraldehyde. Toxicol Lett 95(2):131–139.9635417
Zissu D, Gagnaire F, Bonnet P. 1994. Nasal and pulmonary toxicity of glutaraldehyde in mice. Toxicol Lett 71(1):53–62.8140589