# UPDATE STATEMENT

A Toxicological Profile for Glutaraldehyde, Draft for Public Comment was released in December 2015. This edition supersedes any previously released draft or final profile.

Toxicological profiles are revised and republished as necessary. For information regarding the update status of previously released profiles, contact ATSDR at:

- Agency for Toxic Substances and Disease Registry
  Division of Toxicology and Human Health Sciences
  Environmental Toxicology Branch
  1600 Clifton Road NE
  Mailstop F-57
  Atlanta, Georgia 30329-4027