# APPENDIX B FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR GLUTARALDEHYDE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to glutaraldehyde, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013a; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to glutaraldehyde:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## B.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to glutaraldehyde. The inclusion criteria used to identify relevant studies examining the health effects of glutaraldehyde are presented in Table B-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

## B.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of glutaraldehyde. Studies for other sections of the toxicological profile were also identified in the literature search and screen step. Although these studies were not included in the systematic review process, the results of some studies (e.g., mechanistic studies, toxicokinetic studies) were considered in the final steps of the systematic review. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of glutaraldehyde have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Endocrine effects
Dermal effects
Ocular effects
Body weight effects
Metabolic effects
Other systemic effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Cancer

### B.2.1 Literature Search

The following databases were searched, without date restrictions, in January 2013:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER
- National Pesticide Information Retrieval System (NPIRS)
- Toxic Substances Control Act Test Submissions (TSCATS) and TSCATS2

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

The search strategy used the chemical name, CAS number (i.e., 111-30-8), synonyms, and Medical Subject Headings (MeSH) terms for glutaraldehyde. A total of 5,197 records were identified and imported into EndNote (version 5). After the identification and removal of 1,850 duplicates by EndNote, the remaining 3,337 records were moved to the literature screening step.

An update literature search was conducted in November 2016 of the PubMed, TOXLINE, TOXCENTER, NPIRS, NTP, and TSCATS/TSCATS2 databases utilizing the same search strategy as the January 2013 literature search. The update search identified 2,107 records; 376 records were duplicates of records from the 2013 search and were excluded. A total of 1,731 records were imported into EndNote (version X7). After the identification and removal of an additional 150 duplicates by Endnote, the remaining 1,581 records were moved to the literature screening step. The combined totals for the 2013 and 2016 literature searches were 7,304 records identified; 4,928 records after removal of duplicates.

### B.2.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies examining the health effects of glutaraldehyde:

- Title and Abstract Screen
- Full Text Screen

Title and Abstract Screen. Within the Endnote library, titles and abstracts were screened manually for relevance. Studies that were considered relevant were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study did not meet the inclusion criteria (Table B-1). In the Title and Abstract Screen step, 3,347 records were reviewed in 2013 and an additional 1,581 records were screened in 2016; 291 studies in 2013 and 13 studies in 2016 were considered relevant to Chapter 3 of the toxicological profile and were moved to the next step in the process.

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the Title and Abstract Screen step. Each study was reviewed to determine whether it met the inclusion criteria; however, the quality of the studies was not evaluated at this step of the process. Of the 291 studies in 2013 and 13 studies in 2016 undergoing Full Text Screen, 118 studies in 2013 and 13 records in 2016 did not meet the inclusion criteria; some of the excluded studies were used as background information on toxicokinetics or mechanisms of action or were relevant to other sections of the toxicological profile.

Summaries of the results of the literature search and screening for the draft for public comment profile (literature search conducted in 2013) and post-public comment profile (literature search conducted in 2016) are presented in Figures B-1 and B-2.

Figure B-1 Literature Search and Screen for Glutaraldehyde Health Effect Studies (January 2013)

Figure B-2 Update Literature Search and Screen for Glutaraldehyde Health Effect Studies (November 2016)

## B.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms in Distiller. A summary of the type of data extracted from each study is presented in Table B-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

A summary of the extracted data for each study is presented in the Supplemental Document for Glutaraldehyde and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Section 3.2 of the profile and in the Levels Significant Exposures tables in Section 3.2 of the profile (Tables 3-1, 3-7, and 3-8, respectively).

## B.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for glutaraldehyde identified in human and animal studies are presented in Tables B-3 and B-4, respectively. The available human studies examined a limited number of end points and reported respiratory, dermal, and ocular effects. Animal studies examined a number of end points following inhalation, oral, and dermal/ocular exposure. These studies reported respiratory, gastrointestinal, hematological, renal, dermal, ocular, body weight, and developmental effects. The hematological effects that were observed in one intermediate-duration inhalation exposure animal study were considered to be secondary to the nasal effects or were of questionable toxicological relevance due to the small magnitude of change. The body weight effects were not considered a primary effect and were likely secondary to the morbidity associated with the respiratory, gastrointestinal, or dermal effects. Similarly, the developmental effects appear to be secondary to maternal lethality (inhalation study) or taste aversion to glutaraldehyde-containing water. Thus, the available human and animal studies identify five potential health outcomes for glutaraldehyde: respiratory, gastrointestinal, renal, dermal, and ocular effects; the evidence streams for these outcomes were continued through Steps 5–8 of the systematic review. Animal studies have examined other potential end points, but did not find effects. For example, 16 animal studies examined the liver, but none of the studies reported an adverse effect. In the absence of human studies examining these potential outcomes, these data were considered inadequate for assessing the human hazard potential and were not continued through the systematic review process.

Table B-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

Table B-3 Overview of the Health Outcomes for Glutaraldehyde Evalual

| Systemic effects | | | | | | | | | | | | Immunological effects | Neurological effects | Reproductive effects | Developmental effects | Cancer
| Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Endocrine | Dermal | Ocular | Body weight | Other | Immunological effects | Neurological effects | Reproductive effects | Developmental effects | Cancer
Inhalation studies
Cohort | 6
Cohort | 6
Case control
Population
Controlled exposure | 3
Controlled exposure | 3
Oral studies
Cohort
Case control
Population
Controlled exposure
Dermal studies
Cohort
Case control
Population
Controlled Exposure | | | | | | | | | 2 | 1
Controlled Exposure | | | | | | | | | 2 | 1

Number of studies examining end point | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

Table B-4 Overview of the Health Outcomes for Glutaraldehyde Evaluated in Expen

| Systemic effects | | | | | | | | | | | | Immunological effects | Neurological effects | Reproductive effects | Developmental effects | Cancer
| Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Endocrine | Dermal | Ocular | Body weight | Other | Immunological effects | Neurological effects | Reproductive effects | Developmental effects | Cancer
Inhalation studies
Acute-duration | 11 | | | | | | | | | | 3 | | 2 | 2
Acute-duration | 11 | | | | | | | | | | 2 | | 0 | 0
Intermediate-duration | 8 | 2 | | 2 | | 3 | 2 | | | | 2 | | | 2 | 2
Intermediate-duration | 7 | 0 | | 1 | | 0 | 0 | | | | 2 | | | 0 | 0
Chronic-duration | 2 | 2 | 2 | 2 | | 2 | 2 | 2 | | | 2 | | | 2 | 2
Chronic-duration | 2 | 0 | 0 | 0 | | 0 | 0 | 0 | | | 1 | | | 0 | 0
Oral studies
Acute-duration | | | 7 | 1 | | 7 | 6 | | | | 9 | | | | | 7
Acute-duration | | | 7 | 0 | | 0 | 2 | | | | 1 | | | | | 0
Intermediate-duration | 3 | | 1 | 4 | | 3 | 4 | | | 3 | 5 | | | | 1 | 1
Intermediate-duration | 0 | | 1 | 0 | | 0 | 3 | | | 0 | 1 | | | | 0 | 0
Chronic-duration | 1 | | 2 | 1 | | 1 | 1 | | | | 1
Chronic-duration | 1 | | 2 | 0 | | 0 | 0 | | | | 1
Dermal studies
Acute-duration | | | | | | | | | 7 | 5 | 1
Acute-duration | | | | | | | | | 7 | 5 | 1
Intermediate-duration
Chronic-duration

Number of studies examining end point | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

## B.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### B.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s risk of bias questions (Rooney et al. 2014) and guidance for assessing risk of bias (NTP 2013b). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables B-5, B-6, and B-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table B-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias
Were the comparison groups appropriate?
Confounding bias
Did the study design or analysis account for important confounding and modifying variables?
Did researchers adjust or control for other exposures that are anticipated to bias results?
Performance bias
Did researchers adhere to the study protocol?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Were the outcome assessors blinded to study group or exposure level?
Were the confounding variables assessed consistently across groups using valid and reliable measures?
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table B-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Confounding bias
Did the study design or analysis account for important confounding and modifying variables?
Did researchers adjust or control for other exposures that are anticipated to bias results?
Performance bias
Did researchers adhere to the study protocol?
Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Were the outcome assessors blinded to study group or exposure level?
Were the confounding variables assessed consistently across groups using valid and reliable measures?
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table B-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Confounding bias
Did the study design or analysis account for important confounding and modifying variables?
Did researchers adjust or control for other exposures that are anticipated to bias results?
Performance bias
Were experimental conditions identical across study groups?
Did researchers adhere to the study protocol?
Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Were the outcome assessors blinded to study group or exposure level?
Were the confounding variables assessed consistently across groups using valid and reliable measures?
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of glutaraldehyde health effects studies (observational epidemiology, human experimental, and animal experimental studies) are presented in Tables B-8, B-9, and B-10, respectively.

Table B-8 Summary of Risk of Bias Assessment for Glutaraldehyde—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | | Performance bias | Attrition / exclusion bias | Detection bias | | | | Selective reporting bias | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables? | Did researchers adjust or control for other exposures that are anticipated to bias results? | Did researchers adhere to the study protocol? | Were outcome data complete without attrition or exclusion from analysis? | Were the outcome assessors blinded to study group or exposure level? | Were the confounding variables assessed consistently across groups using valid and reliable measures? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment? | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Cross-sectional cohort studies
NIOSH 1987a | na | − | − | + | + | + | na | + | + | + | Second
NIOSH 1987b | na | − | − | + | + | + | na | + | + | + | Second
Pisaniello et al. 1997 | + | − | − | + | + | + | na | + | + | + | Second
Cohort studies
Norbäck 1988 | + | + | − | + | + | + | na | + | + | + | First
Vyas et al. 2000 | + | − | − | + | + | + | na | + | + | + | Second
Waters et al. 2003 | + | − | − | + | + | + | na | + | + | + | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

Table B-9 Summary of Risk of Bias Assessment for Glutaraldehyde—Human-Controlled Exposure Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Confounding bias | | Performance bias | | Attrition / exclusion bias | Detection bias | | | | Selective reporting bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Did the study design or analysis account for important confounding and modifying variables? | Did researchers adjust or control for other exposures that are anticipated to bias results? | Did researchers adhere to the study protocol? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Were the outcome assessors blinded to study group or exposure level? | Were the confounding variables assessed consistently across groups using valid and reliable measures? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment? | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Inhalation acute exposure
Union Carbide Corp. 1976 | + | na | + | + | + | + | ++ | na | na | + | + | + | First
Cain et al. 2007 | + | na | + | + | + | + | ++ | na | na | + | + | + | First
Outcome: Dermal effects
Dermal acute exposure
Union Carbide Corp. 1966 | + | + | + | + | + | + | + | + | + | + | + | + | First
Union Carbide Corp. 1980 | + | + | + | + | + | + | + | + | + | + | + | + | First
Outcome: Ocular effects
Ocular acute exposure
Cain et al. 2007 | + | na | + | + | + | + | ++ | na | na | + | + | + | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

Table B-10 Summary of Risk of Bias Assessment for Glutaraldehyde—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Confounding bias | | Performance bias | | | Attrition / exclusion bias | Detection bias | | | | Selective reporting bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Did the study design or analysis account for important confounding and modifying variables? | Did researchers adjust or control for other exposures that are anticipated to bias results? | Were experimental conditions identical across study groups? | Did researchers adhere to the study protocol? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Were the outcome assessors blinded to study group or exposure level? | Were the confounding variables assessed consistently across groups using valid and reliable measures? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment? | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Inhalation acute exposure
Werley et al. 1995 (mouse) | + | + | + | + | ++ | + | + | + | + | + | ++ | ++ | + | First
Werley et al. 1995 (guinea pig) | + | + | + | + | + | + | + | + | + | + | ++ | ++ | ++ | First
Gross et al. 1994 (rat) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Gross et al. 1994 (mouse) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Gross et al. 1994 (rat) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Gross et al. 1994 (mouse) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Zissu et al. 1994 (mouse) | + | + | + | + | + | + | + | + | + | na | ++ | ++ | + | First
Zissu et al. 1994 (mouse) | + | + | + | + | + | + | + | + | + | na | ++ | ++ | + | First
Union Carbide Corp. 1992l (rat) | ++ | + | + | + | + | + | + | + | + | + | ++ | + | ++ | First
Union Carbide Corp. 1992d (rat) | ++ | + | + | + | + | + | + | ++ | + | + | ++ | ++ | ++ | First
Union Carbide Corp. 1992e (rat) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Inhalation intermediate exposure
Gross et al. 1994 (rat) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Gross et al. 1994 (mouse) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Gross et al. 1994 (rat) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Gross et al. 1994 (mouse) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1993 (mouse) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1993 (rat) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1993 (mouse) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1993 (rat) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Union Carbide Corp. 1992f (rat) | ++ | + | + | + | + | + | + | ++ | + | + | ++ | ++ | ++ | First
Inhalation chronic exposure
NTP 1999; van Birgelen et al. 2000 (rat) | ++ | + | + | + | + | ++ | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1999 (rat) | ++ | + | + | + | + | ++ | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1999; van Birgelen et al. 2000 (mouse) | ++ | + | + | + | + | ++ | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1999 (mouse) | ++ | + | + | + | + | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Outcome: Gastrointestinal effects
Oral acute exposure
BASF Corp. 1990l (rat) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
BASF Corp. 1990m (rabbit) | + | + | + | + | + | + | + | ++ | + | + | + | + | + | First
BASF Corp. 1991a (rabbit) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
BASF Corp. 1991c (rat) | + | + | + | + | ++ | ++ | + | + | + | + | ++ | ++ | ++ | First
Union Carbide Chem & Plas Co. 1992 (rat) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Union Carbide Corp. 1992a (rat) | + | + | + | + | + | + | + | + | + | + | ++ | + | + | First
Union Carbide Corp. 1992i (mouse) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Union Carbide Chem & Plas Co. 1991dd (dog) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Union Carbide Chem & Plas Co. 1991ee (dog) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
van Miller et al. 2002 (rat) | + | + | + | + | + | ++ | + | ++ | + | na | + | + | + | First
Outcome: Renal effects
Inhalation intermediate exposure
NTP 1993 (rat) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
NTP 1993 (mouse) | + | + | + | + | ++ | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Oral acute exposure
BASF Corp. 1990l (rat) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
BASF Corp. 1990m (rabbit) | + | + | + | + | + | + | + | ++ | + | + | + | + | + | First
BASF Corp. 1991c (rat) | + | + | + | + | ++ | ++ | + | + | + | + | ++ | ++ | ++ | First
BASF Corp. 1991c (rabbit) | + | + | + | + | ++ | ++ | + | + | + | + | ++ | ++ | ++ | First
Union Carbide Chem & Plas Co. 1991f (rat) | + | + | + | + | + | + | + | ++ | + | + | ++ | + | + | First
Union Carbide Chem & Plas Co. 1991o (rat) | ++ | + | + | + | + | + | + | ++ | + | + | ++ | + | + | First
Oral intermediate exposure
Union Carbide Chem & Plas Co. 1991w (mouse) | ++ | + | + | + | ++ | ++ | + | ++ | + | + | ++ | + | + | First
Union Carbide Chem & Plas Co. 1991r (rat) | ++ | + | + | + | ++ | + | + | ++ | + | + | ++ | + | + | First
Union Carbide Chem & Plas Co. 1991ee (dog) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
van Miller et al. 2002 (rat) | + | + | + | + | + | ++ | + | ++ | + | na | + | + | + | First
Outcome: Dermal effects
Dermal acute exposure
Union Carbide Chem & Plas Co. 1991y (mouse) | ++ | + | + | + | + | + | + | + | + | + | ++ | + | + | First
Union Carbide Chem & Plas Co. 1991aa (rabbit) | na | na | + | + | ++ | ++ | na | ++ | na | na | + | + | + | First
Union Carbide Corp. 1992a (rabbit) | + | + | + | + | + | + | + | + | + | + | ++ | + | + | First
Union Carbide Corp. 1992b (rabbit) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Union Carbide Corp. 1992c (rabbit) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Union Carbide Corp. 1992h (rabbit) | na | na | + | + | na | + | na | + | na | na | + | + | + | First
Dermal intermediate exposure
Werley et al. 1996 (rat) | + | + | + | + | + | ++ | + | ++ | + | + | ++ | ++ | ++ | First
Outcome: Ocular effects
Inhalation acute exposure
Hoechst Celanese Corp. 1981 (rat) | ++ | + | + | + | na | + | na | ++ | na | na | ++ | ++ | + | First
Union Carbide Corp. 1992e (rat) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Ocular Acute Exposure
Union Carbide Chem & Plas Co. 1991cc (rabbit) | na | na | na | na | na | + | na | ++ | na | na | ++ | ++ | ++ | First
Union Carbide Chem & Plas Co. 1991k (rabbit) | na | na | + | + | na | + | na | + | na | na | + | + | + | First
Union Carbide Corp. 1992a (rabbit) | + | + | + | + | + | + | + | + | + | + | ++ | + | + | First
Union Carbide Corp. 1992b (rabbit) | + | + | + | + | + | + | + | + | + | + | + | + | + | First
Union Carbide Corp. 1992c (rabbit) | + | + | + | + | + | + | + | + | + | + | + | + | + | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias

## B.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including DHHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to glutaraldehyde and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### B.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to glutaraldehyde and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions in Distiller, which were customized for epidemiology or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human-controlled exposure studies, and experimental animal studies are presented in Tables B-11, B-12, and B-13, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table B-11 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table B-12 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table B-13 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining respiratory, gastrointestinal, renal, dermal, and ocular effects observed in the observational epidemiology, human experimental, and animal experimental studies are presented in Tables B-14, B-15, and B-16, respectively.

A summary of the initial confidence ratings for each outcome is presented in Table B-17. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table B-17.

Table B-14 Presence of Key Features of Study Design for Glutaraldehyde—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Respiratory effects
Cross-sectional cohort studies
NIOSH 1987a | No | Yes | Yes | No | Low
NIOSH 1987b | No | Yes | Yes | No | Low
Pisaniello et al. 1997 | No | Yes | Yes | Yes | Moderate
Cohort studies
Norbäck 1988 | No | Yes | Yes | Yes | Moderate
Vyas et al. 2000 | No | Yes | Yes | No | Low
Waters et al. 2003 | No | Yes | Yes | Yes | Moderate

Table B-15 Presence of Key Features of Study Design for Glutaraldehyde—Human-Controlled Exposure Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group or self-control | Sufficient number of subjects tested | Appropriate methods to measure outcome | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Inhalation acute exposure
Union Carbide Corp. 1976 | Yes | Yes | Yes | No | Moderate
Cain et al. 2007 | Yes | Yes | Yes | No | Moderate
Outcome: Dermal effects
Dermal acute exposure
Union Carbide Corp. 1966 | No | Yes | Yes | No | Low
Union Carbide Corp. 1980 | No | Yes | Yes | No | Low
Outcome: Ocular Effects
Ocular acute exposure
Cain et al. 2007 | Yes | Yes | Yes | No | Moderate

Table B-16 Presence of Key Features of Study Design for Glutaraldehyde—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Inhalation acute exposure
Werley et al. 1995 (mouse) | Yes | No | Yes | Yes | Moderate
Werley et al. 1995 (guinea pig) | Yes | No | Yes | Yes | Moderate
Gross et al. 1994 (rat) | Yes | No | Yes | Yes | Moderate
Gross et al. 1994 (mouse) | Yes | No | Yes | Yes | Moderate
Gross et al. 1994 (rat) | Yes | No | Yes | Yes | Moderate
Gross et al. 1994 (mouse) | Yes | No | Yes | Yes | Moderate
Zissu et al. 1994 (mouse) | Yes | Yes | Yes | Yes | High
Zissu et al. 1994 (mouse) | Yes | Yes | Yes | Yes | High
Union Carbide Corp. 1992l (rat) | Yes | Yes | Yes | Yes | High
Union Carbide Corp. 1992d (rat) | Yes | Yes | Yes | Yes | High
Union Carbide Corp. 1992e (rat) | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Gross et al. 1994 (rat) | Yes | No | Yes | Yes | Moderate
Gross et al. 1994 (mouse) | Yes | No | Yes | Yes | Moderate
Gross et al. 1994 (rat) | Yes | No | Yes | Yes | Moderate
Gross et al. 1994 (mouse) | Yes | No | Yes | Yes | Moderate
NTP 1993 (mouse) | Yes | No | Yes | Yes | Moderate
NTP 1993 (rat) | Yes | No | Yes | Yes | Moderate
NTP 1993 (mouse) | Yes | Yes | Yes | Yes | High
NTP 1993 (rat) | Yes | Yes | Yes | Yes | High
Union Carbide Corp. 1992f (rat) | Yes | Yes | Yes | No | Moderate
Inhalation chronic exposure
NTP 1999; van Birgelen et al. 2000 (rat) | Yes | Yes | Yes | Yes | High
NTP 1999 (rat) | Yes | Yes | Yes | Yes | High
NTP 1999; van Birgelen et al. 2000 (mouse) | Yes | Yes | Yes | Yes | High
NTP 1999 (mouse) | Yes | Yes | Yes | Yes | High
Outcome: Gastrointestinal effects
Oral acute exposure
BASF Corp. 1990l (rat) | Yes | Yes | Yes | Yes | High
BASF Corp. 1990m (rabbit) | Yes | Yes | Yes | Yes | High
BASF Corp. 1991a (rabbit) | Yes | Yes | Yes | Yes | High
BASF Corp. 1991c (rat) | Yes | Yes | Yes | Yes | High
Union Carbide Chem &Plas Co. 1992 (rat) | No | No | Yes | No | Very low
Union Carbide Corp. 1992a (rat) | No | No | Yes | No | Very low
Union Carbide Corp. 1992i (mouse) | No | No | Yes | Yes | Low
Union Carbide Chem &Plas Co. 1991dd (dog) | Yes | No | Yes | No | Low
Oral intermediate exposure
Union Carbide Chem &Plas Co. 1991ee (dog) | Yes | Yes | Yes | No | Moderate
Oral chronic exposure
van Miller et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Outcome: Renal effects
Inhalation intermediate exposure
NTP 1993 (rat) | Yes | Yes | Yes | Yes | High
NTP 1993 (mouse) | Yes | Yes | Yes | Yes | High
Oral acute exposure
BASF Corp. 1990l (rat) | Yes | Yes | Yes | Yes | High
BASF Corp. 1990m (rabbit) | Yes | Yes | Yes | Yes | High
BASF Corp. 1991c (rat) | Yes | Yes | Yes | Yes | High
BASF Corp. 1991c (rabbit) | Yes | Yes | Yes | Yes | High
Union Carbide Chem &Plas Co. 1991f (rat) | Yes | No | Yes | No | Low
Union Carbide Chem &Plas Co. 1991o (rat) | Yes | Yes | Yes | No | Moderate
Oral intermediate exposure
Union Carbide Chem &Plas Co. 1991w (mouse) | Yes | Yes | Yes | No | Moderate
Union Carbide Chem &Plas Co. 1991r (rat) | Yes | Yes | Yes | No | Moderate
Union Carbide Chem &Plas Co. 1991ee (dog) | Yes | Yes | Yes | No | Moderate
Oral chronic exposure
van Miller et al. 2002 (rat) | Yes | Yes | Yes | Yes | High
Outcome: Dermal effects
Dermal acute exposure
Union Carbide Chem &Plas Co. 1991y (mouse) | Yes | No | Yes | Yes | Moderate
Union Carbide Chem &Plas Co. 1991aa (rabbit) | No | No | Yes | No | Very low
Union Carbide Corp. 1992a (rabbit) | No | No | Yes | No | Very low
Union Carbide Corp. 1992b (rabbit) | No | No | Yes | No | Very low
Union Carbide Corp. 1992c (rabbit) | No | No | Yes | No | Very low
Union Carbide Corp. 1992h (rabbit) | No | No | Yes | No | Very low
Dermal intermediate exposure
Werley et al. 1996 (rat) | Yes | Yes | Yes | Yes | High
Outcome: Ocular effects
Inhalation acute exposure
Hoechst Celanese Corp. 1981 (rat) | No | Yes | Yes | Yes | Moderate
Union Carbide Corp. 1992e (rat) | Yes | Yes | Yes | Yes | High
Ocular acute exposure
Union Carbide Chem &Plas Co. 1991cc (rabbit) | No | Yes | Yes | Yes | Moderate
Union Carbide Chem &Plas Co. 1991k (rabbit) | No | No | Yes | No | Very low
Union Carbide Corp. 1992a (rabbit) | No | No | Yes | No | Very low
Union Carbide Corp. 1992b (rabbit) | No | No | Yes | No | Very low
Union Carbide Corp. 1992c (rabbit) | No | No | Yes | No | Very low

Table B-17 Initial Confidence Rating for Glutaraldehyde Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects
Inhalation acute exposure
Human studies
Cross-sectional cohort studies
NIOSH 1987a | Low
NIOSH 1987b | Low | Moderate
Pisanielloetal. 1997 | Moderate
Cohort studies
Norbäck 1988 | Moderate
Vyas et al. 2000 | Low | Moderate
Waters et al. 2003 | Moderate
Controlled exposure
Union Carbide Corp. 1976 | Moderate
Cain et al. 2007 | Moderate | Moderate
Animal studies
Werley et al. 1995 (mouse) | Moderate
Werley et al. 1995 (guinea pig) | Moderate
Gross et al. 1994 (rat) | Moderate
Gross et al. 1994 (mouse) | Moderate
Gross et al. 1994 (rat) | Moderate
Gross et al. 1994 (mouse) | Moderate | High
Zissu et al. 1994 (mouse) | High | High
Zissu et al. 1994 (mouse) | High
Union Carbide Corp. 1992l (rat) | High
Union Carbide Corp. 1992d (rat) | High
Union Carbide Corp. 1992e (rat) | High
Inhalation intermediate exposure
Gross et al. 1994 (rat) | Moderate
Gross et al. 1994 (mouse) | Moderate
Gross et al. 1994 (rat) | Moderate
Gross et al. 1994 (mouse) | Moderate
NTP 1993 (mouse) | Moderate | High
NTP 1993 (rat) | Moderate
NTP 1993 (mouse) | High
NTP 1993 (rat) | High
Union Carbide Corp. 1992f (rat) | Moderate
Inhalation chronic exposure
Animal studies
NTP 1999; van Birgelen et al. 2000 (rat) | High | High
NTP 1999 (rat) | High | High
NTP 1999; van Birgelen et al. 2000 (mouse) | High
NTP 1999 (mouse) | High
Outcome: Gastrointestinal effects
Oral acute exposure
Animal studies
BASF Corp. 1990l (rat) | High
BASF Corp. 1990m (rabbit) | High
BASF Corp. 1991a (rabbit) | High
BASF Corp. 1991c (rat) | High | High
Union Carbide Chem & Plas Co. 1992 (rat) | Very low | High
Union Carbide Corp. 1992a (rat) | Very low
Union Carbide Corp. 1992i (mouse) | Low
Union Carbide Chem & Plas Co. 1991dd (dog) | Low
Oral intermediate exposure
Animal studies
Union Carbide Chem & Plas Co. 1991ee (dog) | Moderate | Moderate
Oral chronic exposure
Animal studies
van Miller et al. 2002 (rat) | High | High
Outcome: Renai effects
Inhalation intermediate exposure
Animal studies
NTP 1993 (rat) | High | High
NTP 1993 (mouse) | High | High
Oral acute exposure
Animal studies
BASF Corp. 1990l (rat) | High
BASF Corp. 1990m (rabbit) | High
BASF Corp. 1991c (rat) | High | High
BASF Corp. 1991c (rabbit) | High | High
Union Carbide Chem & Plas Co. 1991f (rat) | Low
Union Carbide Chem & Plas Co. 1991o (rat) | Moderate
Oral intermediate exposure
Animal studies
Union Carbide Chem & Plas Co. 1991w (mouse) | Moderate
Union Carbide Chem & Plas Co. 1991r (rat) | Moderate | Moderate
Union Carbide Chem & Plas Co. 1991ee (dog) | Moderate
Oral chronic exposure
Animal studies
van Miller et al. 2002 (rat) | High | High
Outcome: Dermal effects
Dermal acute exposure
Human studies
Controlled exposure
Union Carbide Corp. 1966 (irritation) | Low | Low
Union Carbide Corp. 1980 (irritation) | Low | Low
Animal studies
Union Carbide Chem & Plas Co. 1991y (mouse) | Moderate
Union Carbide Chem & Plas Co. 1991aa (rabbit) | Very low
Union Carbide Corp. 1992a (rabbit) | Very low | Moderate
Union Carbide Corp. 1992b (rabbit) | Very low
Union Carbide Corp. 1992c (rabbit) | Very low
Union Carbide Corp. 1992h (rabbit) | Very low
Dermal intermediate exposure
Animal studies
Werley et al. 1996 (rat) | High | High
Outcome: Ocular effects
Ocular acute exposure (airborne vapor)
Human studies
Controlled exposure
Cain et al. 2007 | Moderate | Moderate
Animal studies
Hoechst Celanese Corp. 1981 (rat) | Moderate | High
Union Carbide Corp. 1992e (rat) | High | High
Ocular acute exposure (ocular instillation)
Animal studies
Union Carbide Chem & Plas Co. 1991cc (rabbit) | Moderate
Union Carbide Corp. 1992h (rat) | Very low
Union Carbide Corp. 1992a (rabbit) | Very low | Moderate
Union Carbide Corp. 1992b (rabbit) | Very low
Union Carbide Corp. 1992c (rabbit) | Very low

### B.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for respiratory, gastrointestinal, renal, dermal, and ocular effects are presented in Table B-18. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with glutaraldehyde exposure is presented in Table B-19.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables B-14, B-15, and B-16). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the end points to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Table B-18 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Respiratory Effects
Cross-sectional cohort studies | Moderate | None | Moderate
Cohort studies | Moderate | −1 for risk of bias: studies in risk of bias second tier | Low
Human controlled exposure studies | Moderate | +1 for consistency: threshold levels were consistent across studies | High
Animal studies | High | None | High
Outcome: Gastrointestinal Effects
Animal studies | High | None | High
Outcome: Renal Effects
Animal studies | High | None | High
Outcome: Dermal Effects
Human controlled exposure studies | Low | None | Low
Animal studies | High | None | High
Outcome: Ocular Effects
Human controlled exposure studies | Moderate | None | Moderate
Animal studies | High | +1 consistency: effects were consistently observed | High

Table B-19 Confidence in the Body of Evidence for Glutaraldehyde

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory effects | High | High
Gastrointestinal effects | No data | High
Renal effects | No data | High
Dermal effects | Low | High
Ocular effects | Moderate | High

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## B.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for glutaraldehyde, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence which was established in the sixth step of the systematic review (Section B.6) and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome

A summary of the level of evidence of health effects for glutaraldehyde is presented in Table B-20.

Table B-20 Level of Evidence of Health Effects for Glutaraldehyde

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory effects | High | Health effect (inhalation only) | High
Gastrointestinal effects | No data | No data | No data
Renal effects | No data | No data | No data
Dermal effects | Low | Health effect (dermal contact) | Low
Ocular effects | Moderate | Health effect (ocular contact) | Moderate
Animal studies
Respiratory effects | High | Health effect (inhalation only) | High
Gastrointestinal effects | High | Health effect (oral only) | High
Renal effects | High | Health effect (inhalation, oral) | High
Dermal effects | High | Health effect (dermal contact) | High
Ocular effects | High | Health effect (ocular contact) | High

## B.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure B-3 and described below.

Figure B-3 Hazard Identification Scheme

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for glutaraldehyde are presented in Table B-21.

Table B-21 Hazard Identification Conclusions for Glutaraldehyde

Outcome | Hazard identification
Respiratory effects | Known health effect following inhalation exposure
Gastrointestinal effects | Presumed health effect following oral exposure
Renal effects | Presumed health effect
Dermal effects | Presumed health effect following dermal exposure
Ocular effects | Presumed health effect following ocular exposure