# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Glutaraldehyde Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glutaraldehyde
CAS Numbers: | 111-30-8
Date: | July 2017
Profile Status: | Final
Route: | [x] Inhalation [ ] Oral
Duration: | [x] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 13
Species: | Rat

[underlined: Minimal Risk Level]: 0.001 [ ] mg/kg/day [x] ppm

[underlined: References]:

Gross EA, Mellick PW, Kari FW, . 1994. Histopathology and cell replication responses in the respiratory tract of rats and mice exposed by inhalation to glutaraldehyde for up to 13 weeks. Fundam Appl Toxicol 23(3):348–362.7835535

NTP. 1993. NTP Technical report on toxicity studies of glutaraldehyde (CAS No. 111-30-8) administered by inhalation to F344/N tats and B6C3F1 mice. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services. 25. NIH Publication 93-3348, Number 25.

The rat and mouse studies in the report of NTP (1993) are the same as the studies in the report of Gross et al. (1994). The report of Gross et al. (1994) provides a more detailed quantitative listing of glutaraldehyde-induced nasal lesions.

[underlined: Experimental design]: In a study designed to evaluate the time course of glutaraldehyde-induced nasal lesions, male and female F344 rats and B6C3F1 mice were exposed to glutaraldehyde vapor for 6 hours/day for 1 or 4 days, or 6 or 13 weeks at glutaraldehyde vapor concentrations of 0.0625, 0.125, 0.250, 0.5, or 1 ppm and sacrificed for evaluation of exposure-related nasal lesions.

[underlined: Effect noted in study and corresponding doses]: Exposure-related increased incidences of rats and mice exhibiting selected nasal lesions were observed following exposure to glutaraldehyde vapor at 0.250 ppm 6 hours per day for as little as 1 or 4 days; there were no apparent exposure-related effects on nasal lesion incidences at 0.125 ppm (Table A-1). This study identified a NOAEL of 0.125 ppm, and the lowest LOAEL (0.25 ppm for histopathological nasal lesions) among the acute-duration inhalation studies. Therefore, the principal study (Gross et al. 1994; NTP 1993) and the critical effect (glutaraldehyde-induced histopathological nasal lesions) serve as the basis for derivation of an acute-duration inhalation MRL for glutaraldehyde.

Table A-1 Incidences of Male and Female F344 Rats and B6C3F1 Mice with Selected Histopathologic Nasal Lesions Following Exposure to Glutaraldehyde Vapor 6 Hours/Day for 1 or 4 Days^a^

Species (gender) | Exposure level (PPm) | Squamous exfoliation | | Intraepithelial neutrophils | | Subepithelial neutrophils | | Epithelial erosions
Species (gender) | Exposure level (PPm) | 1 day | 4 days | 1 day | 4 days | 1 day | 4 days | 1 day | 4 days
Rat (male) | 0 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 1/5 (0.2)^b^ | 0/5 | 0/5
Rat (male) | 0.0625 | 1/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5
Rat (male) | 0.125 | 0/4 | 0/5 | 0/4 | 0/5 | 0/4 | 2/5 (0.4) | 0/4 | 0/5
Rat (male) | 0.250 | 1/5 | 0/5 | 1/5 (0.4) | 0/5 | 3/5 (0.8) | 1/5 (0.2) | 1/5 | 1/5
Rat (male) | 0.500 | 3/5 | 3/5 | 2/5 (0.4) | 5/5 (1.4) | 5/5 (1.8) | 5/5 (1.6) | 5/5 | 2/5
Rat (male) | 1.00 | 5/5 | 5/5 | 5/5 (1.2) | 5/5 (2.6) | 5/5 (2.6) | 5/5 (3.4) | | 5/5
Rat (female) | 0 | 0/5 | 0/5 | 0/5 | 1/5 (0.2) | 0/5 | 2/5 (0.4) | 0/5 | 0/5
Rat (female) | 0.0625 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5
Rat (female) | 0.125 | 0/5 | 0/5 | 0/5 | 0/5 | 1/5 (0.4) | 0/5 | 1/5 | 0/5
Rat (female) | 0.250 | 2/5 | 3/5 | 0/5 | 2/5 (0.4) | 1/5 (0.2) | 4/5 (1.4) | 0/4 | 2/5
Rat (female) | 0.500 | 3/5 | 5/5 | 2/5 (0.6) | 5/5 (2.2) | 5/5 (2.4) | 5/5 (2.8) | 4/5 | 3/5
Rat (female) | 1.00 | 4/5 | 5/5 | 4/5 (1.0) | 5/5 (3.4) | 5/5 (2.8) | 5/5 (3.8) | | 5/5
Mouse (male) | 0 | 0/5 | 0/5 | 1/5 (0.2) | 0/5 | 1/5 (0.2) | 0/5 | 0/5 | 0/5
Mouse (male) | 0.0625 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5
Mouse (male) | 0.125 | 0/5 | 0/5 | 1/5 (0.2) | 0/5 | 1/5 (0.2) | 0/5 | 0/5 | 0/5
Mouse (male) | 0.250 | 0/5 | 4/5 | 0/5 | 1/5 (0.2) | 1/5 (0.2) | 2/5 (0.4) | 10/5 | 0/5
Mouse (male) | 0.500 | 4/5 | 2/5 | 1/5 (0.2) | 4/5 (1.8) | 2/5 (0.4) | 4/5 (1.8) | 1/5 | 1/5
Mouse (male) | 1.00 | 5/5 | 5/5 | 5/5 (1.0) | 5/5 (2.8) | 5/5 (1.6) | 5/5 (3.2) | 2/5 | 2/5
Mouse (female) | 0 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5 | 0/5
Mouse (female) | 0.0625 | 0/5 | 0/5 | 0/5 | 1/5 (0.2) | 0/5 | 0/5 | 0/5 | 0/5
Mouse (female) | 0.125 | 0/5 | 0/5 | 0/5 | 0/5 | 1/5 (0.2) | 0/5 | 0/5 | 0/5
Mouse (female) | 0.250 | 0/5 | 2/5 | 0/5 | 1/5 (0.4) | 0/5 | 1/5 (0.4) | 0/5 | 0/5
Mouse (female) | 0.500 | 5/5 | 5/5 | 0/5 | 5/5 (1.0) | 2/5 (0.4) | 5/5 (1.6) | 0/5 | 0/5
Mouse (female) | 1.00 | 4/5 | 5/5 | 1/5 (0.4) | 4/5 (0.8) | 3/5 (1.2) | 5/5 (2.0) | 1/5 | 2/5

a Gray shaded cells suggest a toxicologically significant increased incidence from controls.

b Severity (in parentheses) is the mean for all animals in a group where: 0 = no lesion; 1 = minimal; 2 = mild; 3 = moderate; and 4 = marked.

Sources: Gross etal. 1994; NTP 1993

[underlined: Dose and end point used for MRL derivation]: 0.125 ppm (adjusted for continuous exposure and converted to a human equivalent concentration resulting in a NOAEL_HEC_ of 0.003 ppm); a LOAEL of 0.25 ppm for glutaraldehyde-induced nasal lesions was identified.

[x] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [x] 1 for extrapolation from animals to humans using dosimetric conversion
- [x] 3 for human variability

An uncertainty factor of 1 (rather than the default 10) for extrapolation from animals to humans is justified because: (1) the dosimetric adjustment accounts for differences between rats and humans regarding respiratory tract kinetics, and (2) the critical effect (nasal irritation) is the result of the propensity of glutaraldehyde to react with and cross-link cell membrane proteins (Peters and Richards 1977), a mechanism of action common to laboratory animals and humans. The uncertainty factor for human variability consists of a pharmacokinetic contribution (default of 3) and a pharmacodynamic contribution (default of 3). The propensity of glutaraldehyde to react with and cross-link cell membrane proteins at the portal of entry is not expected to vary significantly. The critical effect (nasal lesions) is independent of glutaraldehyde absorption, distribution, metabolism, and elimination kinetics. Therefore, an uncertainty factor of 1 for intraspecies pharmacokinetics is justified. A default uncertainty factor of 3 for intraspecies pharmacodynamics is retained in the absence of empirical data to suggest otherwise.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Derivation of a HEC based on the NOAEL_ADJ_ was performed according to EPA (1994) cross-species dosimetric methodology for a category 1 gas where inhalation exposure-related effects occur within the extrathoracic region of the respiratory tract (the nasal cavity in the case of glutaraldehyde) using the following equation:

RGDR_ET_ = ( VE / SA_ET_ )_A_ / ( VE / SA_ET_ )_H_ [ equation 4-18 in EPA 1994 ]

where:

- RGDR = ratio of the regional gas dose in animals to that of humans
- VE = minute volume (cm^3^/minute)
- SA = surface area (cm^2^)
- _ET_ = extrathoracic
- _A_ = animal
- _H_ = human

EPA-reported SA_ET_ values for rats (15 cm^2^) and humans (200 cm^2^) were taken from Table 4-4 of EPA (1994). Minute volumes were taken from Table 1-4 of EPA (1988) in which they were presented as m^3^/day (0.14 m^3^/day = 97.2 cm^3^/minute for subchronic exposure of the female F344 rat). Subchronic values were used because the rats were approximately 6–7 weeks old at the initiation of exposures. According to EPA (1994), the default minute volume for humans is 13,800 cm^3^/minute. Therefore:

RGDR_ET_ ( rat ) = ( 97.2 mL / minute / 15 cm^2^ ) / ( 13,800 mL / minute / 200 cm^2^ ) = 6.48 / 69 = 0.0939

The human equivalent NOAEL was calculated according to the following equation:

NOAEL_[ HEC ]_ = NOAEL_[ ADJ ]_ × RGDR_ET_ ( rat ) = 0.031 ppm × 0.0939 = 0.003 ppm ( 3 × 10^− 3^ ppm )

[underlined: Was a conversion used from intermittent to continuous exposure]? The 6-hour exposure was converted to a continuous exposure scenario by multiplying the 6-hour NOAEL of 0.125 ppm by 6 hours/24 hours, resulting in a NOAEL_ADJ_ of 0.031 ppm. The adjustment to account for continuous exposure scenarios is necessary because nasal lesions were observed in glutaraldehyde-exposed rats and mice at lower exposure levels following 6 or 13 weeks of repeated 6-hour exposures than those eliciting nasal lesions following a single 6-hour exposure or repeated 6-hour exposures on 4 consecutive days.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: In a study of Union Carbide Corp (1992d), rhinitis and mild atrophy of the olfactory mucosa were observed in male and female F344 rats exposed to glutaraldehyde vapor at 3.1 ppm for 6 hours/day for 9 exposures in 11 days; at an exposure level of 1.1 ppm, males (but not females) exhibited rhinitis and mild squamous metaplasia of the olfactory mucosa. This study identified a NOAEL of 0.3 ppm and a LOAEL of 1.1 ppm for nasal lesions in the male rats. Zissu et al. (1994) observed histopathological lesions in the respiratory epithelium of septum and naso- and maxilloturbinates of male Swiss OF1 mice exposed to glutaraldehyde vapor for 5 hours/day on 4 consecutive days at 0.3 ppm (the lowest concentration tested); the severity of glutaraldehyde-induced nasal lesions increased with increasing exposure concentration. This study did not identify a NOAEL.

[underlined: Agency Contact (Chemical Manager)]: Susan Zells Ingber, A.B., M.S.P.P.

## Glutaraldehyde Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glutaraldehyde
CAS Numbers: | 111-30-8
Date: | July 2017
Profile Status: | Final
Route: | [x] Inhalation [ ] Oral
Duration: | [ ] Acute [x] Intermediate [ ] Chronic
Graph Key: | 37
Species: | Mouse

[underlined: Minimal Risk Level]: 0.00003 [ ] mg/kg/day [x] ppm

[underlined: References]:

Gross EA, Mellick PW, Kari FW, . 1994. Histopathology and cell replication responses in the respiratory tract of rats and mice exposed by inhalation to glutaraldehyde for up to 13 weeks. Fundam Appl Toxicol 23(3):348–362.7835535

NTP. 1993. NTP Technical report on toxicity studies of glutaraldehyde (CAS No. 111-30-8) administered by inhalation to F344/N rats and B6C3F1 mice. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services. 25. NIH Publication 93-3348, Number 25.

The rat and mouse studies in the report of NTP (1993) are the same as the studies in the report of Gross et al. (1994). The report of Gross et al. (1994) provides a more detailed quantitative listing of glutaraldehyde-induced nasal lesions.

[underlined: Experimental design]: Groups of male and female B6C3F1 mice (10/sex/group) were exposed to glutaraldehyde vapor for 6 hours/day, 5 days/week, for 13 weeks at concentrations of 0, 0.0625, 0.125, 0.25, 0.5, or 1.0 ppm and evaluated for survival, clinical signs, body weight, selected organ and tissue weights, and gross and histopathology (particularly the nasal cavity).

[underlined: Effect noted in study and corresponding doses]: Concentration-related increased incidence and severity of clinical signs of respiratory irritation and histopathologic nasal lesions (exfoliation, inflammation, hyperplasia, and ulceration of nasal squamous epithelium; granulocytes and necrosis in nasal passages; laryngeal squamous metaplasia; necrosis in nasal nares) were reported. Histopathologic nasal lesions were sometimes noted at exposure levels lower than those resulting in overt clinical signs of respiratory tract irritation. In general, glutaraldehyde-induced histopathologic respiratory tract lesions were confined to the anterior nasal cavity and were not observed in lower respiratory tract regions. Incidence data for selected nonneoplastic nasal lesions in the male and female B6C3F1 mice are presented in Table A-2. The incidence data for inflammation in the nasal vestibule/anterior nares of the B6C3F1 female mice from the core study (NTP 1993) were selected to serve as the basis for deriving an intermediate-duration inhalation MRL for glutaraldehyde because this lesion exhibited the lowest effect level (0.0625 ppm). All dichotomous models in the BMDS (Version 2.2) were fit to the incidence data for inflammation in the nasal vestibule/anterior nares of the female mice; the highest exposure group was dropped because the incidence of inflammation in this group was not reported (the study authors stated that “inflammation was a component of ‘squamous exfoliation’ and not diagnosed separately when the latter was present”). A BMR of 10% extra risk was applied. The results of the BMD analysis are summarized in Table A-3.

Table A-2 Incidences of Male and Female B6C3F1 Mice Exhibiting Selected Histopathologic Lesions Following Exposure to Glutaraldehyde Vapor 6 Hours/Day, 5 Days/Week for 13 Weeks in the Core Study of NTP (1993)^a^

| Exposure level (ppm)
| 0 | 0.0625 | 0.125 | 0.250 | 0.500 | 1.000
Males
Nasal passages/turbinates
Respiratory epithelium
Inflammation | 0 | 0 | 0 | 0 | 0 | 4(1.0)^b^
Squamous metaplasia | 0 | 0 | 0 | 0 | 0 | 1 (1-2)
Nasal vestibule/anterior nares
Squamous exfoliation | 0 | 0 | 0 | 1 (1.0) | 2 (1.0) | 9 (2.8)^c^
Inflammation | 0 | 0 | 0 | 0 | 7 (1.1)^c^ | 0^d^
Erosion | 0 | 0 | 0 | 1 (1.0) | 1 (1.0) | 0
Larynx
Squamous metaplasia | 0 | 0 | 0 | 0 | 0 | 7 (1.6)^c^
Necrosis | 0 | 0 | 0 | 0 | 0 | 2 (1.0)
Females
Nasal passages/turbinates
Respiratory epithelium
Inflammation | 0 | 0 | 0 | 0 | 1 (1.0) | 7 (1.4)^c^
Squamous metaplasia | 0 | 0 | 0 | 0 | 0 | 3 (1.0)
Nasal vestibule/anterior nares
Squamous exfoliation | 0 | 0 | 0 | 1 (1.0) | 2 (2.5) | 10 (2.8)^c^
Inflammation^e^ | 0 | 5 (1.0)^b^ | 8 (2.0)^c^ | 8 (1.6)^c^ | 8 (2.5)^c^ | 0^d^
Erosion | 0 | 0 | 1 (1.0) | 0 | 0 | 0
Larynx
Squamous metaplasia | 0 | 0 | 0 | 0 | 0 | 10 (1.6)^c^
Necrosis | 0 | 0 | 0 | 0 | 0 | 2 (1.0)

a Incidence is the number of core-study animals with lesions for groups of 10 animals. Average severity (in parentheses) is based on the number of animals with lesions: 1 = minimal, 2 = mild, 3 = moderate, and 4 = marked.

b Significantly different from control incidence according to Fisher’s exact test (p<0.05).

c Significantly different from control incidence according to Fisher’s exact test (p<0.01).

d Inflammation was a component of “squamous exfoliation” and not diagnosed separately when the latter was present.

e Gray-shaded cells depict the lesion incidence data that were subjected to benchmark dose (BMD) analysis.

Source: NTP 1993

Table A-3 Results from BMD Analysis of Incidences of Female B6C3F1 Mice Exhibiting Inflammation in the Nasal Vestibular/Anterior Nares Following Exposure to Glutaraldehyde Vapor 6 Hours/Day, 5 Days/Week for 13 Weeks

Model | DF | χ^2^ | χ^2^ Goodness of fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (ppm) | BMC_10_ (ppm)
Model | DF | χ^2^ | χ^2^ Goodness of fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (ppm) | BMC_10_ (ppm)
Gamma^c^ | 4 | 10.75 | 0.03 | 0.00 | 1.12 | −2.67 | 53.34
Logistic | 3 | 10.88 | 0.01 | −2.20 | 0.52 | −2.20 | 61.44
LogLogistic ^d^ ^,^ ^e^ | 4 | 1.63 | 0.80 | 0.00 | −0.09 | −0.98 | 47.40 | 0.0065 | 0.0034
LogProbit^d^ | 4 | 8.81 | 0.07 | 0.00 | 0.85 | −2.60 | 51.54
Multistage (1-degree)^f^ | 4 | 10.75 | 0.03 | 0.00 | 0.12 | −2.67 | 53.34
Multistage (2-degree)^f^ | 4 | 10.75 | 0.03 | 0.00 | 1.12 | −2.67 | 53.34
Multistage (3-degree)^f^ | 4 | 10.75 | 0.03 | 0.00 | 1.12 | −2.67 | 53.34
Multistage (4-degree)^f^ | 4 | 10.75 | 0.03 | 0.00 | 1.12 | −2.67 | 53.34
Probit | 3 | 10.99 | 0.01 | −2.26 | 0.50 | −2.26 | 61.92
Weibull^c^ | 4 | 10.75 | 0.03 | 0.00 | 1.12 | −2.67 | 53.34

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. The LogLogistic model was the only model providing adequate fit to the data.

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = dose associated with 10% extra risk); BMD = maximum likelihood estimate of the dose associated with the selected benchmark response; DF = degree of freedom

The Gamma, Logistic, LogProbit, Multistage, Probit, and Weibull models failed to meet conventional goodness-of-fit criteria because their χ^2^ p-values were <0.1. The LogLogistic model provided adequate fit to the data (χ^2^ p-value = 0.80, largest scaled residual −0.98), a BMC_10_ of 0.0065 ppm, and a BMCL_10_ of 0.0034 ppm. Figure A-1 plots predicted incidences of the female mice exhibiting inflammation in the nasal vestibule/nares from the LogLogistic model and observed incidence values from data in Table A-3.

Figure A-1 Predicted and Observed Incidence of Female B6C3F1 Mice Exhibiting Inflammation in the Nasal Vestibular/Anterior Nares Following Exposure to Glutaraldehyde Vapor 6 Hours/Day, 5 Days/Week for 13 Weeks^*^ * BMC and BMCL are associated with a 10% extra risk change from control

[underlined: Dose and end point used for MRL derivation]: BMCL_10_ of 0.0034 ppm, based on inflammation in the nasal vestibular/anterior nares of female B6C3F1 mice inhaling glutaraldehyde vapor.

[ ] NOAEL [ ] LOAEL [x] BMD Analysis

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [x] 1 for extrapolation from animals to humans using dosimetric conversion
- [x] 3 for human variability

An uncertainty factor of 1 (rather than the default 10) for extrapolation from animals to humans is justified because: (1) the dosimetric adjustment accounts for differences between rats and humans regarding respiratory tract kinetics, and (2) the critical effect (nasal irritation) is the result of the propensity of glutaraldehyde to react with and cross-link cell membrane proteins (Peters and Richards 1977), a mechanism of action common to laboratory animals and humans. The uncertainty factor for human variability consists of a pharmacokinetic contribution (default of 3) and a pharmacodynamic contribution (default of 3). The propensity of glutaraldehyde to react with and cross-link cell membrane proteins at the portal of entry is not expected to vary significantly. The critical effect (nasal lesions) is independent of glutaraldehyde absorption, distribution, metabolism, and elimination kinetics. Therefore, an uncertainty factor of 1 for intraspecies pharmacokinetics is justified. A default uncertainty factor of 3 for intraspecies pharmacodynamics is retained in the absence of empirical data to suggest otherwise.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Derivation of a human equivalent concentration (HEC) based on the BMCL_ADJ_ was performed according to EPA (1994) cross-species dosimetric methodology for a category 1 gas where inhalation exposure-related effects occur within the extrathoracic region of the respiratory tract (the nasal cavity in the case of glutaraldehyde) using the following equation:

RGDR_ET_ = ( VE / SA_ET_ )_A_ / ( VE / SA_ET_ )_H_ [ equation 4-18 in EPA 1994 ]

where:

- RGDR = ratio of the regional gas dose in animals to that of humans
- VE = minute volume (cm^3^/minute)
- SA = surface area (cm^2^)
- _ET_ = extrathoracic
- _A_ = animal
- _H_ = human

EPA-reported SA_ET_ values for mice (3 cm^2^) and humans (200 cm^2^) were taken from Table 4-4 of EPA (1994). Minute volumes were taken from Table 1-4 of EPA (1988) in which they were presented as m^3^/day (0.04 m^3^/day = 27.8 cm^3^/minute for subchronic exposure of the female B6C3F1 mouse). According to EPA (1994), the default minute volume for humans is 13,800 cm^3^/minute. Therefore:

RGDR_ET_ ( mouse ) = ( 27.8 mL / minute / 3 cm^2^ ) / ( 13,800 mL / minute / 200 cm^2^ ) = 9.27 / 69 = 0.134

The human equivalent BMCL_10_ was calculated according to the following equation:

BMCL_10 HEC_ = BMCL_10 ADJ_ × RGDR_ET_ ( mouse ) = 0.0006 ppm × 0.134 = 0.00008 ppm ( 8 × 10^− 5^ ppm )

[underlined: Was a conversion used from intermittent to continuous exposure]? The 6-hour/day, 5 days/week exposure was converted to a continuous exposure scenario by multiplying the BMCL_10_ of 0.0034 ppm by 6 hours/24 hours and 5 days/7 days, resulting in a BMCL_10ADJ_ of 0.0006 ppm.

The adjustment to account for continuous exposure scenarios is necessary because nasal lesions were observed in glutaraldehyde-exposed rats and mice at lower exposure levels following 6 or 13 weeks of repeated 6-hour exposures than those eliciting nasal lesions following a single 6-hour exposure or repeated 6-hour exposures on 4 consecutive days.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The principal study (Gross et al. 1994; NTP 1993) included groups of male and female F344/N rats exposed to glutaraldehyde vapor for 6 hours/day, 5 days/week, for 13 weeks at 0.0625, 0.125, 0.250, 0.5, or 1 ppm as well. Nasal lesions similar to those observed in the mice were also noted in the rats (see Table A-4). In a similarly-designed histopathology time-course study that evaluated the progression of nasal lesions for up to 13 weeks (5/species/sex/exposure group/time point) (Gross et al. 1994; NTP 1993), neutrophilic infiltration into intra- and subepithelial regions of the nasal vestibule of female mice was identified as the most sensitive effect and was observed at the lowest exposure level tested (0.0625 ppm) (see Table A-5). The neutrophilic infiltration was consistent with inflammation in the core study, thus providing support to the findings of the core study.

Table A-4 Incidences of Male and Female F344/N Rats Exhibiting Selected Histopathologic Nasal Lesions Following Exposure to Glutaraldehyde Vapor 6 Hours/Day, 5 Days/Week for 13 Weeks in the Core Study of NTP (1993)^a^

| Exposure level (ppm)
| 0 | 0.0625 | 0.125 | 0.250 | 0.500 | 1.000
Males
Respiratory epithelium
Nasoturbinates/septum
Hyperplasia | 0 | 0 | 0 | 0 | 0 | 7 (1.7)^b^
Hyperplasia, goblet cell | 0 | 0 | 0 | 1 (1.0) | 3 (1.0) | 9 (1.4)^b^
Squamous metaplasia | 0 | 0 | 0 | 0 | 0 | 5 (2.0)^c^
Inflammation | 0 | 0 | 0 | 0 | 0 | 7 (1.0)^b^
Lateral wall
Hyperplasia | 0 | 0 | 1 (1.0) | 0 | 4 (1.0)^c^ | 7 (1.7)^b^
Squamous metaplasia | 0 | 0 | 0 | 0 | 1 (1.0) | 7 (2.5)^b^
Olfactory epithelium
Degeneration | 0 | 0 | 0 | 0 | 0 | 1 (2.0)
Nasal vestibule/anterior nares
Squamous exfoliation | 0 | 0 | 0 | 1(1.0) | 4 (1.0)^c^ | 9 (1.1)^b^
Inflammation | 0 | 1 (1.0) | 0 | 0 | 0 | 3 (1.0)
Females
Respiratory epithelium
Nasoturbinates/septum
Hyperplasia | 0 | 0 | 0 | 0 | 0 | 4 (1.7)^c^
Hyperplasia, goblet cell | 0 | 0 | 0 | 0 | 0 | 8 (1.2)^b^
Squamous metaplasia | 0 | 0 | 0 | 0 | 0 | 5 (1.4)^c^
Inflammation | 0 | 0 | 0 | 1 (1.0) | 0 | 5 (1.2)^c^
Lateral wall
Hyperplasia | 0 | 0 | 0 | 1 (2.0) | 2 (1.0) | 8 (1.6)^b^
Squamous metaplasia | 0 | 0 | 0 | 1 (3.0) | 0 | 8 (2.0)^b^
Olfactory epithelium
Degeneration | 0 | 0 | 0 | 0 | 0 | 2 (1.5)
Nasal vestibule/anterior nares
Squamous exfoliation | 0 | 0 | 0 | 3 (1.3) | 7 (1.1)^b^ | 9 (1.7)^b^
Inflammation | 1 (1.0) | 0 | 0 | 0 | 0 | 0
Erosion | 0 | 0 | 0 | 0 | 1 (1.0) | 2 (2.0)

a Incidence is the number of core-study animals with lesions for groups of 10 animals. Average severity (in parentheses) is based on the number of animals with lesions: 1 = minimal, 2 = mild, 3 = moderate, and 4 = marked.

b Significantly different from control incidence according to Fisher’s exact test (p<0.01).

c Significantly different from control incidence according to Fisher’s exact test (p<0.05).

Source: NTP 1993

Table A-5 Incidences of Male and Female F344/N Rats and B6C3F1 Mice Exhibiting Selected Histopathologic Lesions in the Nasal Vestibule Following Exposure to Glutaraldehyde Vapor 6 Hours/Day, 5 Days/Week For 13 Weeks in the Histopathology Time-Course Study^a^

| Exposure level (ppm)
| 0 | 0.0625 | 0.125 | 0.250 | 0.500 | 1.000
Male rat
Squamous exfoliation | 0 | 0 | 0 | 2 | 2 | 2
Intraepithelial neutrophils | 5 (1.2)^b^ | 3 (0.8) | 5 (1.0) | 5 (1.2) | 4 (1.2) | 5 (1.6)
Intraepithelial neutrophils | 5 (1.0) | 4 (1.0) | 5 (1.2) | 5 (1.6) | 5 (1.4) | 5 (2.0)
Epithelial erosions | 1 | 1 | 0 | 1 | 1 | 1
Squamous metaplasia | 1 (0.2) | 0 | 0 | 0 | 5 (2.0) | 5 (3.0)
Female rat
Squamous exfoliation | 0 | 0 | 0 | 0 | 2 | 4
Intraepithelial neutrophils | 1 (0.2) | 0 | 1 (0.4) | 3 (1.0) | 2 (0.8) | 4 (1.4)
Intraepithelial neutrophils | 2 (0.4) | 0 | 1 (0.8) | 3 (1.0) | 4 (1.8) | 4 (2.0)
Epithelial erosions | 0 | 0 | 0 | 0 | 0 | 1
Squamous metaplasia | 0 | 0 | 0 | 0 | 3 (1.2) | 5 (2.6)
Male mouse
Squamous exfoliation | 0 | 0 | 0 | 3 | 1 | –^c^
Intraepithelial neutrophils | 0 | 0 | 1 (0.2) | 4 (1.6) | 5 (2.6) | –
Intraepithelial neutrophils | 0 | 1 (0.2) | 2 (0.8) | 5 (2.2) | 5 (2.8) | –
Epithelial erosions | 0 | 0 | 0 | 1 | 3 | –
Squamous metaplasia | 0 | 0 | 0 | 0 | 1 (0.2) | –
Female mouse
Squamous exfoliation | 0 | 0 | 0 | 0 | 1/4 | –
Intraepithelial neutrophils | 0 | 4 (2.0) | 5 (2.4) | 5 (3.2) | 4/4 (2.8) | –
Intraepithelial neutrophils | 2 (0.4) | 5 (2.0 | 5 (2.8) | 5 (3.2) | 4/4 (2.8) | –
Epithelial erosions | 0 | 0 | 0 | 0 | 0/4 | –
Squamous metaplasia | 0 | 0 | 0 | 0 | 1/4 (0.5) | –

a Gray shaded cells suggest a toxicologically significant increased incidence from controls.

b Incidence is the number of animals with lesions for groups of five animals unless a denominator is given. Severity (in parentheses) was averaged for five animals/group where: 0 = no lesion, 1 = minimal, 2 = mild, 3 = moderate, and 4 = marked.

c Not evaluated, all animals died.

Sources: Gross et al. 1994: NTP 1993

[underlined: Agency Contact (Chemical Manager)]: Susan Zells Ingber, A.B., M.S.P.P.

## Glutaraldehyde Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Glutaraldehyde
CAS Numbers: | 111-30-8
Date: | July 2017
Profile Status: | Final
Route: | [ ] Inhalation [x] Oral
Duration: | [ ] Acute [ ] Intermediate [x] Chronic
Graph Key: | 46
Species: | Rat

[underlined: Minimal Risk Level]: 0.1 [x] mg/kg/day [ ] ppm

[underlined: Reference]: van Miller JP, Hermansky SJ, Losco PE, . 2002. Chronic toxicity and oncogenicity study with glutaraldehyde dosed in the drinking water of Fischer 344 rats. Toxicology 175(1–3):177–189.12049846

[underlined: Experimental design]: In a 2-year chronic toxicity and oncogenicity study, Fischer 344 rats (100/sex/group) were administered glutaraldehyde (50.0–51.3% w/w aqueous solution) in the drinking water at concentrations of 0, 50, 250, or 1,000 ppm for 52 weeks (first interim sacrifice of 10/sex/group), 78 weeks (second interim sacrifice of 10/sex/group), or up to 104 weeks (main group). Author-reported average glutaraldehyde doses were 0, 4, 17, and 64 mg/kg/day, respectively, for the males and 0, 6, 25, and 86 mg/kg/day, respectively, for the females. Animals were observed for survival, clinical signs, body weight, and food and water consumption. Eyes were examined by indirect ophthalmoscopy before the start of dosing and after weeks 52, 78, and 104. Hematology and serum chemistry evaluations were performed at weeks 12, 26, 52, 78, and 104 (10 rats/sex/group). Urine was collected from 10 rats/sex/group during weeks 12, 25, 51, 77, and 103 for urinalysis. All surviving rats were sacrificed at week 104. At sacrifice, liver, kidneys, brain, heart, adrenal glands, and testes were removed and weighed. Comprehensive gross and histopathologic examinations were performed on all animals.

[underlined: Effect noted in study and corresponding doses]: Treatment-related effects included slightly depressed body weight and lesions of the stomach. The depressions in body weight were typically <10% in magnitude. Gross pathology revealed gastric irritation (multifocal color change, mucosal thickening, nodules, and ulceration affecting primarily the nonglandular mucosa) in 250- and 1,000-ppm male and female rats at 52-, 78-, and 104-week sacrifice (prevalences of 30, 10–20, and 10%, respectively) and in animals that died prior to scheduled sacrifice (prevalence of 40%). Histopathology revealed significantly increased incidences of 1,000-ppm male and female rats with mucosal hyperplasia in the stomach at terminal sacrifice (males: 7/51 versus 1/56 controls; females 7/56 versus 1/62 controls), but not at 52- or 78-week interim sacrifices. Incidences of this lesion at the lower dose levels were not significantly different from those of controls. This study identified NOAELs of 4 and 6 mg/kg/day for the male and female rats, respectively, and LOAELs of 17 and 25 mg/kg/day for male and female rats, respectively, for gastric irritation (multifocal color change, mucosal thickening, nodules, and ulceration affecting primarily the nonglandular mucosa).

[underlined: Dose and end point used for MRL derivation]: 4 mg/kg/day

[x] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [x] 10 for extrapolation from animals to humans
- [x] 3 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? No.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Wistar rats (50/sex/group) were administered glutaraldehyde (50.5% active ingredient) in the drinking water for up to 24 months at concentrations of 0, 100, 500, or 2,000 ppm (approximate daily glutaraldehyde intakes of 0, 3, 16, and 60 mg/kg/day, respectively, for the males and 0, 5, 24, and 88 mg/kg/day, respectively, for the females) (BASF 2013; Confidential 2002). Increased incidences of non-neoplastic lesions were observed at the 2,000 ppm exposure level and involved the larynx (squamous metaplasia in males [18/50 versus 0/50 controls] and females [30/50 versus 0/50 controls]) and trachea (squamous metaplasia in males [4/50 versus 0/50 controls] and females [11/50 versus 0/50 controls]). In addition, significant trends for increasing incidence with increasing glutaraldehyde concentration were noted for diffuse metaplasia in the larynx of male and female rats, focal metaplasia in the larynx of females, focal squamous metaplasia in the trachea of males and females, and diffuse metaplasia in the trachea of females. Metaplasia was nearly always accompanied by accumulation of keratin detritus in the laryngeal and/or tracheal lumen. Some high-dose rats with laryngeal/tracheal metaplasia also exhibited foreign body granulomas in the lung and/or inflammation in the tracheal lumen. Significantly increased incidence of erosion/ulceration was noted in the glandular stomach of 2,000-ppm females. Purulent inflammation in the nasal cavity was seen in three males and six females of the highest exposure level.

[underlined: Agency Contact (Chemical Manager)]: Susan Zells Ingber, A.B., M.S.P.P.