# 8 REFERENCES

* Cited in text

Acher AJ, Boderie P, Yaron B. 1989. Soil pollution by petroleum products: 1. Multiphase migration of kerosene components in soil columns, Journal of Contaminated Hydrology 4(4):333–345.
Adachi K. 1981. Mass fragmentographic determination of polymethylbiphenyl in foods contaminated with petroleum products. Bull Environ Contam Toxicol 26(6):737–744.6894880
*Agarwal V, Gupta A. 1974. Accidental poisonings in children. Indian Pediatr 11(9):617–621.4443066
Ahlberg M, Berghem L, Nordberg G, 1983. Chemical and biological characterization of emissions from coal- and oil-fired power plants. Environ Health Perspect 47:85–102.6825622
*Ahrens W, Jockel K, Patzak W, 1991. Alcohol, smoking, and occupational factors in cancer of the larynx: A case control study. Am J Ind Med 20:477–493.1785612
*Air Force. 1989. The installation restoration program toxicology guide: Volume 4. Contract no. 1891-A076-Al. Wright Patterson Air Force Base, OH: Harry G. Armstrong Aerospace Medical Research Laboratory, Aerospace Medical Division, Air Force Systems Command. DOE interagency agreement no. 1891-A076-Al.
*Akamaguna AI, Odita JC. 1983. Radiology of kerosene poisoning in young children. Ann Trop Paediatr 3(2):85–88.6197013
Akhtar S, Zahid S, Khan M. 1992. Risk-factors associated with hydropericardium syndrome in broiler flocks. Veterinary Record 131(21):481–484.1471326
*Alden CL. 1986. A review of unique male rat hydrocarbon nephropathy. Toxicol Pathol 14(l): 109–111.2424069
*Aldy D, Siregar R, Siregar H. 1978. Accidental poisoning in children with special reference to kerosene poisoning. Paediatr Indones 18( l-2):45–50.652367
*Algren J, Rodgers G JR. 1992. Intravascular hemolysis associated with hydrocarbon poisoning, Pediatric Emergency Care 8( 1):34–35.1603687
Al-Saad H, Al-Timari A. 1993. Sources of hydrocarbons and fatty acids in sediment from Hor Al-Hammar. Marine Pollution Bulletin 26(10):559.
Allen RL, Manning W, McKenzie KD, 1992a. Development of a monoclonal antibody immunoassay for the detection of gasoline and diesel fuel in the environment. Assoc Am Railroads Contaminated Soils-Diesel Fuel Contamination Research Triangle Park NC.
*Allen R, Manning W, McKenzie K, 1992b. A rapid and sensitive immunoassay for the detection of gasoline and diesel fuel in contaminated soil. Journal of Soil Contamination 1(3):227.
Almaguer D, Wilcox T. 1993. Indoor environmental quality “from the ground up.” Applied Occupational and Environmental Hygiene 8(8):677–680.
*Ames BN, McCann J, Yamasaki E. 1975. Methods for detecting carcinogens and mutagens with the Salmonella/mammalian-microsome mutagenicity test. Mutat Res 3 1:347–364.
Amitai I, Mogle P, Godfrey S, 1983. Pneumatocele in infants and children: Report of 12 cases. Clin Pediatr (Phila) 22(6):420–422.6839622
Amoozegar A, Warrick AW, Fuller WH. 1986. Movement of selected organic liquids into dry soils. Hazardous Waste and Hazardous Materials 3:29–41.
*Anderson JW, Neff JM. 1977. Accumulation and release of petroleum hydrocarbons by edible marine animals. Proceedings of the International Symposium on recent advances in the assessment of the health effects of environmental pollution, Paris, June 24-28, 1974. Vol. 3:1461–1469.
*Andersson P, Demirbuker M, Blomberg L. 1992. Quantitative hydrocarbon group- analysis of gasoline and diesel fuel by supercritical fluid chromatography. Journal of Chromatography 595(1-2):301–311.
*Andrasko J. 1983. The collection and detection of accelerant vapors using porous polymers and Curie point pyrolysis wires coated with active carbon. J Forensic Sci 28(2):330–344.
*Andrews J, Lieberman S. 1994. Neutral-network approach to qualitative identification of fuels and oils from laser-induced fluorescence-spectra. Analytica Chimica Acta 285(1-2):237–246.
Andrews GE, Abbass MK, Williams PT, 1989. Factors influencing the composition of the organic fraction of diesel particulates. Journal of Aerosol Science 20(8):1373–1376.
*Annobil SH. 1983. Chest radiographic patterns following kerosene poisoning in Ghanaian children. Clin Radio1 34(6):643–646.
*Annobil SH. 1988. Skin bullae following kerosene poisoning. Ann Trop Pediatr 8(1):45–47.
*Annobil SH, Ogunbiyi OA. 1991. Pulmonary radiology changes in kerosene poisoning in the Asir region of Saudi Arabia. Ann Trop Paediatr 11(4):391–395.1721801
Anonymous. 1980. A recommended standard for occupational exposure to refined petroleum products. Cincinnati, OH: Robert A. Taft Laboratories. Document no. HRP-0030436/O.
Anonymous. 1982. Mutagenicity, teratogenicity, and carcinogenicity. In: Selected petroleum products. Environ Health Criteria 20:50–61.
*APHA. 1985. Standard methods for the examination of water and wastewater. 16th ed. Washington, DC: American Public Health Association.
*API. 1979a. Acute dermal toxicity: API #78-3: #2 home heating oil (10% cat). Washington, DC: American Petroleum Institute. Project no. 1443-D.
*API. 1979b. Primary eye irritation: API #79-6: Diesel fuel (marketplace sample). Washington, DC: American Petroleum Institute. Project no. 1443-B.
*API. 1979c. Inhalation/teratology study in rats: Fuel oil. Washington, DC: American Petroleum Institute. Document no. FYI-AX-0183-0230.
API. 1979d. Rat acute oral toxicity study: API #78-3: #2 Home heating oil (10% cat). Washington, DC: American Petroleum Institute. Project no. 1443-E.
API. 1979e. Rat acute oral toxicity study: API #79-6: Diesel fuel (marketplace sample). Washington, DC: American Petroleum Institute. Project no. 1443-E.
*API. 1979f. Skin sensitization: API #79-6: Diesel fuel (marketplace sample). Washington, DC: American Petroleum Institute. Project no. 1443-C.
*API. 19798. Teratology study in rats: Diesel fuel. Washington, DC: American Petroleum Institute. Document no. FYI-AX-0183-0230.
*API. 1980a. Acute dermal toxicity: API #79-6: Diesel fuel (marketplace sample). Washington, DC: American Petroleum Institute. Project no. 1443-D.
API. 1980b. Primary skin irritation: API #78-3: #2 Home heating oil (10% cat). Washington, DC: American Petroleum Institute. Project no. 1443-A.
*API. 1981. Mutagenicity evaluation of diesel fuel in the mouse dominant lethal assay. Washington, DC: American Petroleum Institute.
*API. 1989. Short-term dermal tumorigenesis study of selected petroleum hydrocarbons in male CD-l mice. Initiation and promotion phases: Final Report API#36-32643. American Petroleum Institute Washington DC.
*API. 1990. Basic petroleum data book: Petroleum industry statistics. Washington, DC: American Petroleum Institute 10(3):Section VII.
*API. 1991. Basic petroleum data book: Petroleum industry statistics. Washington, DC: American Petroleum Institute 1 l(3):Section VII.
*Apitz S, Borbridge L, Bracchi K, 1992. Fluorescent response of fuels in soils: Insights into fuel-soil interactions. Naval Command, Control and Ocean Surveillance Center, San Diego, CA Jun. 92:9.
Apte MG, Traynor GW, Froehlich DA, 1989. The impact of add-on catalytic devices on pollutant emissions from unvented kerosene heaters. JAPCA 39(9):1228–1230.2585000
Arif JM, Khan SG, Aslam M, 1991. Early biochemical changes in kerosene exposed rat lungs. Chemosphere 22(8):705–712.
Arif J, Khan S, Aslam M, 1992. Diminution in kerosene-mediated induction of drug metabolizing enzymes by asbestos in rat lungs. Pharmacology and Toxicology 71(1):37–40.1326107
*Army. 1986. Literature survey and data base assessment: Microbial fate of diesel fuel and fog oils. Project no. 3E162720A835. Frederick, MD: U.S. Army Bioengineering Research and Development Laboratory, Fort Detrick. Document no. PC A03/MFAOl.
Arthur M, O’Brien G, Marsh S, 1992. Evaluation of innovative approaches to simulate degradation of jet fuels in subsoils and groundwater. Battelee Columbus Labs, OH Jun. 92:35.
Ashkenazi AE, Berman SE. 1961. Experimental kerosene poisoning in rats: Use of ^14^C labelled hendecane as indicator of absorption. Pediatrics 28:642–649.
ASTM. 1992. Standard specifications for fuel oils. American Society for Testing and Materials. Philadelphia, PA.
ASTM. 1994a. Standard specification for aviation turbine fuel. American Society for Testing and Materials. Philadelphia, PA.
ASTM. 1994b. Standard specification for diesel fuel oils. American Society for Testing and Materials, Philadelphia, PA.
Athens W, Jockel K, Patzak W, 1991. Alcohol, smoking, and occupational factors in cancer of the larynx: A case-control study. American Journal of Industrial Medicine 20(4):477–493.1785612
*ATSDR. 1989. Toxicological profile for benzene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1990a. Toxicological profile for toluene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1990b. Toxicological profile for lead. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1991 a. Toxicological profile for total xylenes. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1991b. Toxicological profile for polycyclic aromatic hydrocarbons. Atlanta, GA: US. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Azizi BH O, Henry RL. 1990. Effects of indoor air pollution on lung function of primary school children in Kuala Lumpur. Pediatr Pulmonol 9(1):24–29.2388776
*Azizi BHO, Henry RL. 1991. The effects of indoor environmental factors on respiratory illness in primary school children in Kuala Lumpur. Int J Epidemiol 20(1):144–150.2066213
*Bailey B, Kohl K. 1991. Chemical analysis of aromatics in diesel fuels. Southwest Research inst, San Antonio, TX.
Bakatubia M, Talleyrand D. 1978. [Infant pneumopathy from kerosene ingestion.] Ann Sot Belg Med Trop 58(3):251–253. (French)
Baldachin BJ, Malmed PM. 1964. Clinical and therapeutic aspects of kerosene poisoning: A series of 200 cases. Br Med J 2:28–30.14147771
*Baldwin RE. 1977. Adsorption-elution technique for concentration of hydrocarbon vapors. Arson Anal News1 1(6):9–12.
Barbari TA, King CJ. 1982. Equilibrium distribution coefficients for extraction of chlorinated hydrocarbons and aromatics from water into undecane. Environ Sci Technol 16(9):624–627.22284207
Barber DM, Cousin DA, Seawtight D. 1987. An episode of kerosene poisoning in dairy heifers. Vet Ret 120(19):462–463.
Barnard K, Gordon D. 1991. Sunken vessels and aircraft containing hazardous materials in Puget Sound. Environmental Protection Agency. Seattle, WA.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk estimates. Regul Toxicol Pharmacol 8:471–486.3222488
*Barrientos A, Ortuno MT, Morales JM, 1977. Acute renal failure after use of diesel fuel as shampoo. Arch Intern Med 137:1217.901091
Barter RA, Byrne MJ, Carter RF. 1966. Pulmonary hyaline membrane: Late results of injury to the lung linings. Arch Dis Child 41(219):489–495.6006137
Bartha R. 1990. Bioremediation of hydrocarbon-contaminated soil: A feasibility study. New Brunswick, NJ: Rutgers University, Department of Biochemistry and Microbiology.
*Bartha R. Atlas RM. 1977. The microbiology of oil spills. Adv Appl Microbial 22:225–266.
Beamon RF, Siegel CH, Landers G, 1976. Hydrocarbon ingestion in children: A six-year retrospective study. JACEP 5(10):771–775.1018351
Bechtold WE, Dutcher JS, Brooks AL, 1985. Contribution of primary aromatic amines to the mutagenicity of gasifer tars and coal oils. Mutat Res 155:7–16.3969083
Beck LS, Hepler DI, Hansen SL. 1983. The acute toxicology of selected petroleum hydrocarbons. In: MacFarland HN, ed. Proceedings of the Symposium on the toxicology of petroleum hydrocarbons, Washington, DC, May 1982. Washington, DC: American Petroleum Institute, 1–12.
*Beck LS, Hepler DL, Hansen KL. 1984. The acute toxicology of selected petroleum hydrocarbons. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modern environmental toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc.
Behera D, Jindel SK. 1991. Respiratory symptoms in Indian women using domestic cooking fuels. Chest 100(2):355–358.
*Beliles RP, Mecler FJ. 1983. Inhalation teratology of jet fuel A, fuel oil and petroleum naphtha in rats. In: MacFarland HN, ed. Proceedings of the Symposium on the toxicology of petroleum hydrocarbons, Washington, DC, May 1982. Washington, DC: American Petroleum Institute, 233–238.
*Belkin F, Esposito GG. 1986. Dynamic thermal stripping procedure for the analysis of fuel oil no. 2 and kerosene in water. J Chromatogr Sci 24:216–219.
Benestad C, Moeller M, Osvik A, 1985. Air pollution from biomass heated boilers compared with that from waste incineration and oil combustion. Energy Biomass 1985:819–821.
Benz RD, Beltz PA. 1980. Cytogenic toxicologic testing with dogs. Environ Mutagen 2:312–313.
*Berwick M, Leaderer BP, Stowijk JA, 1989. Lower respiratory symptoms in children exposed to nitrogen dioxide from unvented combustion sources. Environment International 15( l-6):369–373.
*Bianchi AP, Varney MS, Phillips J. 1991. Analysis of industrial solvent mixtures in water using a miniature purge-and-trap device with thermal desorption and capillary gas chromatography-mass spectrometry. J Chromatogr 557(1-2):429–439.
Bieri R. 1974. Identification of hydrocarbons in and extract from estuarine water accommodated No. 2 fuel oil. International Marine Pollution Monitoring (Petroleum) Symposium Gaithersburg, Md.
Biles RW. 1984. Summary of results of skin painting bioassays of mid-distillates. Submitted by RW Biles, Exxon Corporation, NJ to CA Halder, Standard Oil Company, Chicago, IL, October 22, 1984.
Biles RW, McKee RH. 1983. Toxicological testing for hazard identification in synthetic fuel technology. Dev Toxicol Environ Sci 11:13–21.6677449
*Biles R, McKee R, Lewis S, 1988. Dermal carcinogenic activity of petroleum-derived middle distillate fuels. Toxicology 53:301–314.3212789
Birmingham DJ. 1988. Contact dermatitis and related dermatoses associated with petroleum recovery and use. Occupational Medicine: State of the Art Reviews 3(3):511–523.
Blackburn GR, Deitch RA, Schreiner CA, 1984. Estimation of the dermal carcinogenic activity of petroleum fractions using a modified Ames assay. Cell Biol Toxicol 1:67–80.6401126
*Blackburn GR, Deitch RA, Schreiner CA, 1986. Predicting carcinogenicity of petroleum distillation fractions using a modified Sulmonella mutagenicity assay. Cell Biol Toxicol 2:63–84.3267446
Blackbum G, Deitch R, Schreiner C, 1987. Testing of petroleum middle distillates in a modified Ames assay. Environmental Mutagenesis 9:15.
*Blakeslee JR, Elliot AM, Carter LJ. 1983. In vitro effects of polynuclear aromatic hydrocarbons on FeSV transformation of human cells. In: Cooke M, Dennis AJ, eds. Proceedings of the Seventh International Symposium on polynuclear aromatic hydrocarbons: Formation, metabolism, and measurement. Columbus, OH: Battelle Press, 123–133.
*Blumer M, Souza G, Sass J. 1970. Hydrocarbon pollution of edible shellfish by an oil spill. Marine Biology 5: 195–202.
Bobra AM, Brown JR, Clark AG. 1978. Bacterial degradation of crude oil and oil compounds in pure and mixed culture systems. In: Afghan BK, MacKay D, eds. Hydrocarbons and halogenated hydrocarbons in the aquatic environment. New York, NY: Plenum Press, 521–530.
*Boehm PD, Quinn JG. 1973. Solubilization of hydrocarbons by the dissolved organic matter in sea water. Geochima et Cosmochimica Acta 37( 11):2459–2477.
*Boehm PD, Quinn JG. 1974. The solubility behavior of no. 2 fuel oil in sea water. Mar Pollut Bull 5(7):101–105.
Boffetta P, Cardis E, Vainio H, 1991. Cancer risks related to electricity production. European J Cancer 27(11):1504–1519.1835869
*Boylan DB, Tripp BW. 1971. Determination of hydrocarbons in seawater extracts of crude oil and crude oil fractions. Nature 230(5288):44–47.4930964
Bracher V, Neuschaefer A, Allen W. 1991. The effect of intrauterine infusion of kerosene on the endometrium of mares. Journal of Reproduction an Fertility S44:706–707.
Brambley MR, Darby WP. 1984. Portable kerosene heaters and indoor air quality. In: Pibazari M, Devinny JS, eds. Environmental engineering: Proceedings of the 1984 Specialty Conference, University of Southern California, June 25-27, 1984. New York, NY: American Society of Civil Engineers, 155–160.
Bratton L. 1975. Ingestion of charcoal lighter fluid. J Pediatr 87:633–637.1159594
Braun AG, Nichinson BB, Horowitz PB. 1982. Inhibition of tumor cell attachment to concanavalin A-coated surfaces as an assay for teratogenic agents: Approaches to validation. Teratogenesis Carcinog Mutagen 2(3-4):343–354.6130634
Braun AG, Busby WF, Liber HL, 1987. Chemical and toxicological characterization of residential oil burner emissions: 2. Mutagenic, tumorigenic, and potential teratogenic activity. Environ Health Perspect 73:235–246.3665866
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. Washington, DC: The C.V. Mosby Company, 175–176.
*Brown J III, Burke B, Dajani AS. 1974. Experimental kerosene pneumonia: Evaluation of some therapeutic regimens. J Pediatr 84(3):396–401.4149566
*Bruner RH. 1984. Pathologic findings in laboratory animals exposed to hydrocarbon fuels of military interest. In: Mehlman MA, Hemstreet GP II I, Thorpe JJ, , eds. Advances in modern environmental toxicology. Volume VII: Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 133–140.
Bruner RH, Pitts LL. 1983. Nephrotoxicity of hydrocarbon propellants to male, Fischer-344 rats. Proceedings of the 13th Conference on environmental toxicology, University of California, Irvine, CA, November 1982. Dayton, OH: Overlook Branch, 337–363.
*Brtinner S, Rovsing J, Wulf. 1964. Roentgenographic changes in the lungs of children with kerosene poisoning. Am Rev Respir Dis 89:250–254.14120086
Brunner R. 1983. Nephrotoxicity of hydrocarbon propellents to male Fishcehr-344 rats. Proceedings of the 13th Conference on environmental toxicology, University of California, Irvine, November 1982. Dayton, OH: Overlook Branch, p. 337–363.
Buch N, Ahmed K, Sethi A. 1991. Poisoning in children. Indian Pediatr 28(5):521–524.1752680
*Buckley EN, Jonas RB, Pfaender FK. 1976. Characterization of microbial isolates from an estuarine ecosystem: Relationship of hydrocarbon utilization to ambient hydrocarbon concentrations. Appl Environ Microbial 32(2):232–237.
*Budavari S, O’Neil MJ, Smith A, 1989. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. Rahway, NJ: Merck and Co., 834.
Buetzer P. 1985. [Handling of toxic substances: Experience and hazard: A vapor hazard index for substances.] Swiss Chem 7(9):25–26, 28. (German)
Burley S, Huber G. 1971. The effect of toxic agents commonly ingested by children in antibacterial defenses in the lungs [Abstract]. Pediatr Res 5:405
*Burns KA, Teal JM. 1979. The West Falmouth oil spill: Hydrocarbons in the salt marsh ecosystem. Estuarine and Coastal Marine Science 8(4):349–360.
Butcher BT, Salvaggio JE. 1986. Occupational asthma. J Allergy Clin Immunol 78(4 Part 1):547–556.3534048
*Butt AI, Riazuddin S, Shakoori AR, 1988. Isolation and identification of petroleum hydrocarbon degrading bacteria from the local environments. Pak J Zoo1 20(4):391–399.
Bwibo NO. 1969. Accidental poisoning in children in Uganda. Br Med J 4(683):601–602.5356551
Caceres T, Soto H, Lissi E, 1983. Indoor house pollution: Appliance emissions and indoor ambient concentrations. Atmos Environ 17(5):1009–1013.
Cain PM. 1975. Comparison of kerosenes using capillary gas liquid chromatography. J Forensic Sci 15(4):301–308.
Cain D, Helsel DR, Ragone SE. 1989. Preliminary evaluations of regional ground-water quality in relation to land use. Ground Water 27(2):230–244.
Calkins WH, Deye JF, Hartgrove RW, 1981. Synthetic crude oils from coal: Mutagenicity and tumor-initiation screening tests. Department of Energy Symposium Series 54:462–470.
Carmichael P, Pfau W, Ni She M, 1991. Formation of DNA-adducts in human and mouse skin following treatment with used engine oil and elucidation of some of the contributing PAHs by 32P-poslabeling (meeting abstract). Proc Annu Meet Am Assoc Cancer Res; 32:A582.
*Carpenter CP, Geary DL, Myers RC, 1976. Petroleum hydrocarbon toxicity studies: XI. Animal and human response to vapors of deodorized kerosene. Toxicol Appl Pharmacol 36(3):443–456.941146
*Carpenter CP, Kinkead ER, Geary DL Jr, 1975. Petroleum hydrocarbon toxicity studies: I. Methodology. Toxicol Appl Pharmacol 32:246–262.1154392
*Casaco A, Gonzalez R, Arruzazabala L, 1982. Studies on the effects of kerosine aerosol on airways of rabbits. Allergol Immunopathol 10(5):361–366.
Casaco A, Gonzalez R, Arruzazabala L, 1983. Effects of kerosine on the airways of experimental animals. Rev Cubana Med 22(5):490–500.
Casaco A, Carvajal D, Noa M, 1985a. Effects of kerosene on airway sensitization to egg albumin in guinea pig. Allergol Immunopathol 13(3):235–239.
*Casaco A, Garcia M, Gonzalez R, 1985b. Induction of acetylcholinesterase inhibition in the guinea pig trachea by kerosene. Respiration 48( 1):46–49.4023437
*Casaco A, Gonzalez R, Arruzazabala L, 1985c. Kerosene aerosol induces guinea pig airway hyperreactivity to acetylcholine. Respiration 47(3):190– 195.4001575
Casaco A, Gonzalez R, Arruzazabala L, 1989. Effect of cooking emissions on airways of rabbits. Revista Cubana de Ciencias Biologicas
*CELDS. 1991. Computer-Environmental Legislative Data Systems. University of Illinois, Urbana, IL. June 20, 1991.
*Chan WC, Colbourne MJ, Fung SC, 1979. Bronchial cancer in Hong Kong 1976-1977. Br J Cancer 39(2):182–192.435367
Chandra RK. 1968. Kerosene swallowing [Editorial]. J Trop Pediatr 14(1):1–2.5300887
Chang D, Lopez I. 1992. Determination of Kerosene and #2 diesel in soil by purge and trap vs. extraction procedure. Journal of Soil Contamination 1(3):239.
Chawla SC, Nehta SP. 1973. A study of host and environment factors in cases of accidental poisoning admitted in Irwin hospital. Indian J Med Res 61(5):724–731.4763953
Chemical Regulation Reporter. 1987. Furnace oil promotes, not initiates, skin cancer, AMOCO report says in risk notice. The Bureau of National Affairs, Inc. (November 27, 1987), 1516–1517.
Chen T, Lam W, Raymond R. 1992. Novel Diesel-fueled engine for microclimate cooling for the individual soldier. Tecogen, Inc Waltham, MA.
Chet I, Mitchell R. 1976. Petroleum hydrocarbons inhibit decomposition of organic matter in sea water. Nature 261(5558):308–309.
Chlobowska Z, Madej A. 1978. [Use of gas chromatography for identification of hydrocarbon products in contaminated water and other materials: II.] Z Zagdnien Kryminal 13:103–112. (Polish).
*Christensen LB, Larsen TH. 1993. Method for determining the age of diesel oil spills in the soil. Ground Water Monitor Remediation 13(4): 142.
Chu TC, Chu EJ. 1966. Thin-layer chromatography of methyl esters of porphyrins, chlorins, and related compounds with Eastman “chromagram.” J Chromatogr 21(1):46–51.5940145
*Clark C, Walter M, Ferguson P, 1988. Comparative dermal carcinogenesis of shale and petroleum derived distillates. Toxicology and Industrial Health 4:11–22.3388444
Clarkson SG, Tom BL, Babcock AJ, 1984. Results of testing unvented kerosene heaters in a house: Gas emissions, surface temperatures and fuel consumption rates. In: Proceedings of the 77th Annual Meeting of the Air Pollution Control Association, San Francisco, CA, June 24-29, 1984, Vol. 2. Pittsburgh, PA: APCA.
CLPSD. 1990. Contract Laboratories Program Statistical Database. Washington, DC: U.S. Environmental Protection Agency. January, 1990.
Coast Guard. 1985. Chemical Hazard Response Information System (CHRIS): Hazard assessment handbook. Washington, DC: U.S. Department of Transportation, U.S. Coast Guard. Commandant Instruction M.16465.12A.
*Coleman WE, Melton RG, Slater RW, 1981. Determination of organic contaminants by the Grob closed-loop-stripping technique. J Am Water Works Assoc 71: 119–125.
*Coleman WE, Munch JW, Streicher RP, 1984. The identification and measurement of components in gasoline, kerosene, and no. 2 fuel oil that partition into the aqueous phase after mixing. Arch Environ Contam Toxicol 13:171–178.
Comar CL, Nelson N. 1975. Health effects of fossil fuel combustion products: Report of a workshop. Environ Health Perspect 12: 149–170.1227856
*Commonwealth of Massachusetts. 1983. Massachusetts Water Quality Standards. Boston, MA: Massachusetts Surface Water Quality Standards. Massachusetts 314 CMR 4.00.
*Commonwealth of Virginia. 1988. Commonwealth of Virginia State Water Control Board Regulations. Richmond, VA: Commonwealth of Virginia State Water Control Board Regulations, Water Quality Standards.
*Conaway CC, Schreiner CA, Cragg ST. 1984. Mutagenicity evaluation of petroleum hydrocarbons. In: Mac Farland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modem toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 89–107.
*CONCAWE. 1985. Health aspects of petroleum fuels - general principles. Report no. 2/85. Oil Companies’ European Organization for Environmental and Health Protection. The Hague, Netherlands, p. 3–19. Document no. PB85-230480.
*Connell DW, Miller GJ. 1980. Petroleum hydrocarbons in aquatic ecosystems: Behavior and effects of sublethal concentrations: Part 1. Crit Rev Environ Control 11(1):37–104.
Connell DW, Miller GJ. 1981. Petroleum hydrocarbons in aquatic ecosystems: Behavior and effects of sublethal concentrations: Part 2. Crit Rev Environ Control 11(2):105–162.
Cookson D, Smith B. 1992. Observed and predicted properties of jet and diesel fuels formulated from coal-liquefaction and fischer-tropsch feedstocks. Energy and Fuels 6(5):581–585.
*Cooney JJ, Silver SA, Beck EA. 1985. Factors influencing hydrocarbon degradation in three freshwater lakes. Microb Ecol 11(2):127–137.24221301
Cooper J, Mattie D. 1993. Developmental toxicity of JP-8 jet fuel in the rat. Toxicologist 13(1):78.
Cooper KR, Alberti RR. 1984. Effect of kerosene heater emissions on indoor air quality and pulmonary function. Am Rev Respir Dis 129(4):629–631.6424521
*Cooper RE, Hedrick HG. 1976. Activity of soil bacteria on petroleum waste adjacent to an active oil well. Soil Sci 122(6):331–338.
Corapcioglu MY, Hossain MA. 1990. Theoretical modeling of biodegradation and biotransformation of hydrocarbons in subsurface environments. J Theor Biol 142(4):503–516.2338835
*Coruh M, Inal H. 1966. Kerosene poisoning in children with special reference to lung complication. Turk J Pediatr 8(1):36–42.5915005
*Cowan MJ, Jenkins LJ Jr. 1981. Navy toxicity study of shale and petroleum JP-5 aviation fuel and diesel fuel marine. In: Griest WH, Guerin MR, Coffin DL, eds. Health effects investigation of oil shale development. Ann Arbor, MI: Ann Arbor Science Publishers, Inc., 129–139.
*Cox BA, Anderson JW, Parker JC. 1975. An experimental oil spill: The distribution of aromatic hydrocarbons in the water, sediment, and animal tissues within a shrimp pond. In: Proceeding of the Conference on the Prevention and Control of Oil Pollution, p. 607–612.
*Crisp AJ, Bhalla AK, Hoffhrand BJ. 1979. Acute tubular necrosis after exposure to diesel fuel. Br Med J 2:177.
*Cundell AM, Traxler RW. 1976. Psychrophilic hydrocarbon-degrading bacteria from Narragansett Bay, Rhode Island, U.S.A. Material und Organismen ll(l):l-17.
*Custance SR, McCaw PA, Kopf AC, 1992. Environmental fate of the chemical Mixtures: Crude oil, JP-5, mineral spirits, and diesel fuel. Journal of Soil Contamination 1(4):379.
Daffner RH, Jimenez JP. 1973. The double gastric fluid level in kerosene poisoning. Radiology 106(2):383–384.4684480
Dahlgran JR. 1981. Simultaneous detection of total and halogenated hydrocarbons in complex environmental samples. Journal of High Resolution Chromatography and Chromatography Communications 4(8):393–397.
*Daisey J, Gundel L. 1991. Tracing the sources of indoor aerosols using evolved gas-analysis. Aerosol Science and Technology 14(1):25–32.
Daisey JM, Hershman RJ, Kneip TJ. 1982. Ambient levels of particulate organic matter in New York City, USA, in winter and summer. Atmos Environ 16(9):2162–2168.
Dalbey W, Lock S, Garfinkel S, 1982. Inhalation exposures of rats to aerosolized diesel fuel. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. The toxicology of petroleum hydrocarbons. Washington, DC: American Petroleum Institute, 13–25.
*Dalbey W, Lock S. 1983. Chemical characterization and toxicological evaluation of airborne mixtures: Inhalation toxicology of diesel fuel obscurant aerosol in Sprague-Dawley rats: Final report, phase 2: Acute exposures. Oak Ridge, TN: Oak Ridge National Laboratory. ORN/TM-8867.
*Dalbey W, Henry M, Holmberg R, 1987. Role of exposure parameters in toxicity of aerosolized diesel fuel in the rat. J Appl Toxicol 7(4):265–275.3624787
*Danielson LL, Gentner WA. 1970. Effect of solvent composition on inactivation of several phenyl and thio carbamate herbicides in soil. Proceedings of the Northeastern Weed Control Conference 24:308–312.
deAraufo CR, Flores H. 1978. Improved spectrophotometric vitamin A assay. Clin Chem 24(2):386.
*Deichmann WB, Kitzmiller KV, Witherup BS, 1944. Kerosene intoxication. Ann Intern Med 21:803–823.
De la Lande Cremer CN, Van der Veen L, Douwes HT. 1978. [Effect of petroleum products on the development of spring wheat.] Rapp Inst Bodemvruchtbaarheid 12: 1–22. (Dutch)
*Dell‘acqua R, Bush B. 1973. Microdetermination of gasoline in potable waters by gas chromatography. Int J Environ Anal Chem 3:141–146.4793347
DeMaria MJ, Arola L, Alemany M. 1989. Effect of the percutaneous administration of hexadecane, 2,4-dinitrophenol, gas oil, and fuel oil on weight changes in mice. Toxicol Environ Chem 19(1-2):35–45.
Demarini DM, Brimer PA, Hsie AW. 1984. Cytotoxicity and mutagenicity of coal oils in the CHO/HGPRT assay. Environ Mutagen 6(4):517–527.6468346
*Dibble JT, Bartha R. 1979. Rehabilitation of oil-inundated agricultural land: A case history. Soil Sci 128( 1):56–60.
*Dice WH, Ward G, Kelley J, 1982. Pulmonary toxicity following gastrointestinal ingestion of kerosene. Ann Emerg Med 11: 138–142.7065488
DiCicco G, Naviglio A, Spinazzola A. 1986. [Characterization of emissions produced by thermoelectric power plants fired with fuel oil and coal: Evaluation of the relative health and carcinogenic hazards associated with them.] Acqua Aria 7:667–674. (Italian)
*Diem D, Kerfoot H, Ross B. 1988. Field evaluation of a soil-gas analysis method for detection of subsurface diesel fuel contamination: Second national outdoor action conference on aquifer restoration, ground water monitoring and geophysical methods. National Water Well Association Dublin, OH.
DOE. 1978. Embryo culture in teratological surveillance and serum proteins in development. Contract no. EY-76-S-02-3139. Washington, DC: U.S. Department of Energy. Document no. C00-3139-31.
DOE. 1980. Health effects of coal technologies: Research needs. Washington, DC: U.S. Department of Energy. Report no. MTR-79W15902.
DOE. 1982. Exploratory research on mutagenic activity of coal-related materials. Contract no. DOE/PC/42692-T2. Washington, DC: U.S. Department of Energy. Document no. DE83012791.
DOE. 1986a. Comparative toxicity of crude and refined coal liquids and analogous petroleum products: I. Chronic dermal toxicity in mice. Contract no. DE-AC05-84OR21400. Washington, DC: U.S. Department of Energy. Document no. DE86004762.
DOE. 1986b. Comparison of pollutant emission rates from unvented kerosene and gas space heaters. Washington, DC: U.S. Department of Energy. Document no. DE86015133.
DOE. 1986c. Effects of coal rank on the chemical composition and toxicological activity of coal liquefaction materials. Contract no. DE-AC06-76RLO-1830. Washington, DC: U.S. Department of Energy. Document no. DE86011015.
DOE. 1986d. Evaluation of occupational health and environmental hazards associated with storage and processing of fossil fuels. Washington, DC: U.S. Department of Energy. Document no. DOE/LC/10924-2168.
DOE. 1986e. Sources of nitrogen oxide pollution in the indoor environment. Contract no. BNL-39209. Washington, DC: U.S. Department of Energy. Document no. DE87006742.
DOE. 1988a. Indoor air quality in 300 homes in Kingston/Harriman, Tennessee. Contract no. DE-AC05-84OR21400. Washington, DC: U.S. Department of Energy. Document no. ORNL-6401.
DOE. 1988b. Use of medium scale experiments to determine smoke characteristics. Washington, DC: U.S. Department of Energy. Document no. DE89008333.
DOE. 1989a. Impact of kerosene heater usage on indoor NO_2_ exposures in 50 East Tennessee homes. Washington, DC: U.S. Department of Energy, in cooperation with Harvard University School of Public Health, Boston, MA.
DOE. 1989b. Tracing the sources of indoor aerosols using evolved gas analysis. Washington, DC: U.S. Department of Energy. Document no. DE90000182.
DOE. 1989c. West Valley demonstration project: Implementation of the kerosene mitigation plan. Contract no. DE-AC07-81NE 44139. Washington, DC: U.S. Department of Energy, Assistant Secretary for Nuclear Energy. Document no. DE 88015385.
DOE. 1993. Petroleum supply monthly, February 1993. Department of Energy Office of Oil and Gas. Washington DC.
DOE/ EIA 1993a. Winter fuels report, week ending April 2, 1993. Department of Energy Office of Oil and Gas. Washington DC.
DOE/ EIA 1993b. Winter fuels report, week ending November 26, 1993. Department of Energy, Office of Oil and Gas. Washington DC.
DOE/HHS/EPA. 1980. Health effects of coal technologies: Research needs. Washington, DC: Department of Energy/Department of Health and Human Services/Environmental Protection Agency, Federal Interagency Committee on the Health and Environmental Effects of Energy Technologies. Document no. PB81-118796.
Dong JI, Bozzelli JW. 1989. Benzo-a-pyrene levels in several indoor environments with kerosene heaters and wood-burning fireplaces. Chemosphere 18(9-10):1829–1836.
DOT. 1984. Emergency response book. Washington, DC: Department of Transportation, U.S. Government Printing Office.
*DOT. 1989a. Hazardous materials table. US. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101 Appendix A.
*DOT. 1989b. List of hazardous substances and reportable quantities. U.S. Department of Transportation. Federal Register 54 (185): 39501–39505.
*Dudin AA, Rambaud-Cousson A, Thalji A, 1991. Accidental kerosene ingestion: A three-year prospective study. Ann Trop Paediatr 11(2):155–161.1715147
Eade NR, Taussig LM, Marks MI. 1974. Hydrocarbon pneumonitis. Pediatrics 54(3):351–357.4606628
*Easley JR, Holland JM, Gipson LC, 1982. Renal toxicity of middle distillates of shale oil and petroleum in mice. Toxicol Appl Pharmacol 65:84–91.7147259
Ebert AG, Schleifer CR, Hess SM. 1966. Absorption, disposition, and excretion of 3H-mineral oil in rats. J Pharm Sci 55:923–929.5918529
Eckardt RE. 1983. Petroleum and petroleum products. Encyclopaedia of Occupational Health and Safety 2:1649–1652.
Edelfors S, Raven-Jonsen A. 1992. Effect of organic solvents on nervous cell membrane as measured by changes in the calcium magnesium ATPase activity and fluidity of synaptosomal membrane. Pharmacology and Toxicology 70(3): 181– 187.1533717
*Edgerton SA, Coutant RW, Henley MV. 1987. Hydrocarbon fuel spill dispersion on water: A literature review. Chemosphere 16(7):1475–1487.
el-Habashi A, Fahin A, Kamel A. 1969. Toxi-pathological studies on kerosene. J Egypt Med Assoc 52(5):421–426.5345060
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier Publishing, 944–945.
Ellenton JA, Hallett DJ. 1981. Mutagenicity and chemical analysis of aliphatic and aromatic fractions of Prudhoe Bay crude oil and fuel oil no. 2. J Toxicol Environ Health 8(5-6):959–972.7200152
Elmgren R, Hansson S, Larsson U, 1983. The “Tsesis” oil spill: Acute and long-term impact on the benthos. Mar Biol (Berlin) 73(1):51–65.
Emmelin A, Nyskrom L, Wall S. 1993. Diesel exhaust exposure and smoking - A case-referent study of lung-cancer among Swedish dock workers. Epidemiology 4(3):237–244.7685637
*EPA. 1977. Criteria for the evaluation of permit applications for ocean dumping of material. Washington, DC: U.S. Environmental Protection Agency. Federal Register 42(7):2476–2482.
EPA. 1978. Combustion research on characterization of particulate organic matter in flames. Research Triangle Park, NC: U.S. Environmental Protection Agency, Industrial Environmental Research Laboratory.
EPA. 1980a. Characterization of kerosene heater emissions inside two mobile homes. Contract no. EPA-600-D-90-115. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Research and Exposure Assessment Laboratory, Harvard School of Public Health, Boston, MA. Document no. PB90-263013.
EPA. 1980b. Substantial risk report EPA number 8EHQ-0879-0301. Environmental Protection Agency. Washington DC.
*EPA. 1981. Long term effects of the barge FLORIDA oil spill. Contract no. EPA-R-801001-02. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Municipal Environmental Research Laboratory. Report no. EPA-600/2-81-012.
EPA. 1983. Summary of preliminary results from lifetime skin-painting study. TSCA Chem-in-Prog Bull 4 #3:10 May 1983. Environmental Protection Agency. Washington DC.
*EPA. 1984. Permeability of compacted soils to solvents mixtures and petroleum products. In: Proceedings of the Tenth Annual Research Symposium for land disposal of hazardous waste, Ft. Mitchell, Kentucky, April 3-5, 1984. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Municipal Environmental Research Laboratory, 124– 137. Contract no. 68-03-3131.
EPA. 1985. Literature survey of environmental concerns associated with in situ coal/oil shale operations. Research Triangle Park, NC: U.S. Environmental Protection Agency, Air and Engineering Research Laboratory. Document no. EPA-68-02-3994.
*EPA. 1986a. Literature survey of environmental concerns associated with in situ coal/oil shale operations. Contract no. 68-02-3994. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Air and Energy Engineering Research Laboratory. EPA report no. EPA/600/7-86/022.
*EPA. 1986b. Movement of selected organic liquids into dry soils. Ada, OK: U.S. Environmental Protection Agency, Office of Research and Development, Robert S. Kerr Environmental Research Laboratory. EPA report no. EPA/600/J-86052.
*EPA. 1986c. Quality criteria for water. Washington, DC: U.S. Environmental Protection Agency. EPA 440/5-86-001.
EPA. 1987a. U.S. EPA evaluation of volumetric UST leak detection methods. In: Proceedings of the 13th Annual Research Symposium, Cincinnati, OH, May 6-8, 1987. Cincinnati, OH: U.S. Environmental Protection Agency, 164– 171.
EPA. 1987b. Human exposure to mutagens from indoor combustion sources. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. Report no. EPA/600/D-87/144.
*EPA. 1987c. Identification and listing of hazardous waste. Washington, DC: U.S. Environmental Protection Agency. Federal Register 52(15):2522–2528.
EPA. 1988a. Evaluating sources of indoor air pollution. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Air and Energy Engineering Research Laboratory. EPA report no. EPA/600/D-88/086.
*EPA. 1988b. General pretreatment regulations for existing and new sources of pollution. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 403.2 Appendix B.
*EPA. 1988c. General pretreatment regulations for existing and new sources. Washington, DC: U.S. Environmental Protection Agency. Federal Register 53(200):40610–40616.
EPA. 1988d. Integrated approach to the characterization of particle and organic emissions from unvented kerosene space heaters. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Air and Energy Engineering Research Laboratory. EPA report no. EPA/600/D-88-25 1.
EPA. 1988e. Laboratory studies of vacuum-assisted steam stripping of organic contaminants from soil. In: Proceedings of the Fourteenth Annual Research Symposium for land disposal, remedial action, incineration, and treatment of hazardous wastes, Cincinnati, Ohio, May 9-l 1, 1988. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Risk Reduction Engineering Laboratory, 65–92.
EPA. 1988f. Review and evaluation of the influence of chemicals on the conductivity of soil clays. Contract no. EPA-R-808824. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Hazardous Waste Engineering Research Laboratory. EPA report no. EPA/600/2-88/016.
EPA. 19888. Preliminary results of chronic skin-painting studies on mice. TSCA Chem-in Prog Bull 9 #2:5 m=Mar 1988. Environmental Protection Agency. Washington DC.
EPA. 1989a. Case study: Multipollutant indoor air quality study of 300 homes in Kingston/Harriman, Tennessee. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. Contract no. EPA-R-81 1650.
*EPA. 1989b. Pesticides required to be reregistered: List C. U.S. Environmental Protection Agency. Federal Register 54 (104): 30846–30855.
*EPA. 1989c. Reregistration. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 152.146.
EPA. 1990a. Case study: Multipollutant indoor air quality study of 300 homes in Kingston/Harriman, Tennessee. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. EPA report no. EPA/600/D-901126.
EPA. 1990b. Characterization of kerosene heater emissions inside two mobile homes. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Atmospheric Research and Exposure Assessment Laboratory. EPA report no. EPA/600/09.
EPA. 1990c. Characterizations of population and usage of unvented kerosene space heaters. Contract no. 68-02-4284. Washington, DC: U.S. Environmental Protection Agency. EPA report no. EPA/600/7-90/004.
EPA. 1990d. Evaluating sources of indoor air pollution. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Air and Energy Engineering Research Laboratory. EPA report no. EPA/600/13.
*EPA. 1990e. Interim methods for development of inhalation reference concentrations. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA/600/8-88/066F.
EPA. 1990f. Unvented kerosene heater emissions from mobile homes: Studies on indoor air particles, semi-volatile organics, carbon monoxide, and mutagenicity. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. Report no. EPA/600/D-90022.
*EPA 1991a. C_9_ aromatic hydrocarbon fraction. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 799.2175.
*EPA. 1991b. Constituents prohibited as other than trace contaminants. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 227.6.
*EPA. 1991c. Method 602 - Purgeable aromatics; Method 610-Polynuclear aromatic hydrocarbons; Method 625 - Base/neutrals and acids. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 136, Appendix A.
*EPA. 1992. Analysis of emissions from residential oil furnaces. EPA Office of Research and Development, Air and Energy Engineering Research Laboratory. Research Triangle Park, North Carolina. EPA/600/A-92/136.
Eppley Z. 1992. Assessing indirect effects of oil in the presence of natural variation: The problem of reproductive failure in South Polar Skuas during the Bahla Paraisa oil spill. Marine Pollution Bulletin 25(9-12):307–312.
*ERNS. 1992. Emergency Response Notification System. Washington, DC: US. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
Ewisman MP, Swindoll S. 1991. Determination of petroleum hydrocarbon toxicity with microtox. Bulletin of Environmental Contamination Toxicology 47(6):811.1786452
Fagbule D, Joiner K. 1992. Kerosene poisoning in childhood: a 6-year prospective study at the University of Ilorin Teaching Hospital. West African Journal of Medicine 11(2):116–121.1390371
*Farrington JW, Davis AC, Frew NM, 1982a. No. 2 fuel oil components in Mytilis edulis: Retention and release after an oil spill. Mar Biol 66:15–26.
*Farrington JW, Tripp BW, Teal JM, 1982b. Biogeochemistry of aromatic hydrocarbons in the benthos of microcosms. Toxicol Environ Chem 5(3-4):331–346.
Felsenstein WC, Staiff DC, Miller GC. 1976. Acute demeton poisoning in a child. Arch Environ Health 31(5):266–269.973741
*Fidler AT, Baker EL, Letz RE. 1987. Estimation of long term exposure to mixed solvents from questionnaire data: A tool for epidemiological investigations. Br J Ind Med 44(2):133–141.3814546
*Flowers TH, Pulford ID, Duncan HJ. 1984. Studies on the breakdown of oil in soil. Environmental Pollution (Ser B) 8(1):71–82.
Foley JC, Dreyer NB, Bradley SA, 1954. Kerosene poisoning in young children. Radiology 62:817–829.13167415
*Frankenberger WT Jr. 1988. Use of urea as a nitrogen fertilizer in bioreclamation of petroleum hydrocarbons in soil. Bull Environ Contam Toxicol 40( 1):66–68.2830930
*Frankenberger WT Jr, Johanson JB. 1982. Influence of crude oil and refined petroleum products on soil dehydrogenase activity. J Environ Qua1 11(4):602–607.
*Freeman J, Federici T, McKee R. 1993. Evaluation of the contribution of chromic skin irritation and selected compositional parameter to the tumorigenicity of petroleum middle distillates in mouse skin. Toxicology 38:103–112.
Frommer U, Ullrich V, Staudinger H, 1972. The monooxygenation of n-heptane by rat liver microsomes. Biochimica Biophysics Acta 280:487–494.
Frosch PJ, Wissing C. 1982. Cutaneous sensitivity to ultraviolet light and chemical irritants. Arch Dermatol Res 272(3-4):269–278.7165336
*FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Chemical Communication Subcommittee, Federal-State Toxicology and Regulatory Alliance Committee. Washington, DC: U.S. Environmental Protection Agency.
*Galin T, Gerstl Z, Yaron B. 1990a. Soil pollution by petroleum products: III. Kerosene stability in soil columns as affected by volatilization. J Contam Hydrol 5(4):375–385.
*Galin T, McDowell C, Yaron B. 1990b. The effect of volatilization on the mass flow of a nonaqueous pollutant liquid mixture in an inert porous medium: Experiments with kerosene. J Soil Sci 41(4):631–641.
Gallagher J, George M, Kohan M, 1993. Detection and comparison of DNA adducts after in vitro and in vivo diesel emission exposures. Environmental Health Perspectives 99:225–228.8319629
Gallagher J, Phillips D, Pojinsky B, 1992. Formation of adducts in rat lungs over time following inhalation to organic diesel emissions and inorganic carbon black, and TIO2 particles [abst]. Proc Annu Meet Am Assoc Cancer Res 33:A884.
*Garcia M, Gonzalez R. 1985. Uncoupling of the calcium pump of the sarcoplasmic reticulum by kerosene. Toxicol Lett 28(1):59–64.4060196
Garcia M, Gonzalez R, Casaco A. 1988a. Biochemical mechanisms in the effects of kerosene on airways of experimental animals. Allergol Immunopathol 16(5):363–367.
*Garcia M Casaco A, Arruzazabala L, 1988b. Role of chemical mediators in bronchoconstriction induced by kerosene. Allergol Immunopathol 16(6):421–423.
*Gaworski CL, MacEwen JD, Vernot EH, 1984. Comparison of the subchronic inhalation toxicity of petroleum and oil shale JP-5 jet fuels. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modern environmental toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, 33–47.
*Gearing PJ, Gearing JN. 1982a. Behavior of no. 2 fuel oil in the water column of controlled ecosystems. Marine Environmental Research 6(2): 115–132.
*Gearing PJ, Gearing JN. 1982b. Transport of no. 2 fuel oil between water column, surface microlayer and atmosphere in controlled ecosystems. Marine Environmental Research 6(2):133–143.
*Gearing PJ, Gearing JN, Pruell RJ, 1980. Partitioning of no. 2 fuel oil in controlled estuarine ecosystems: Sediments and suspended particulate matter. Environ Sci Technol 14(9):1129-l 136.
*Gerarde HW. 1959. Toxicological studies on hydrocarbons: V. Kerosene. Toxicol Appl Pharmacol 1:462–474.13827408
*Gerarde HW. 1963. Toxicological studies on hydrocarbons: IX. The aspiration hazard and toxicity of hydrocarbons and hydrocarbon mixtures. Arch Environ Health 6:329–341.13947290
*Gerhart JM, Hatoum NS, Halder CA, 1988. Tumor initiation and promotion effects of petroleum streams in mouse skin. Fundam Appl Toxicol 11:76–90.3209019
Giammona ST. 1967. Effects of furniture polish on pulmonary surfactant. Am J Dis Child 113:658–663.6026569
Gleason NN, Gosselin RE, Hodge HC. 1963. Clinical toxicology of commercial products: Acute poisoning (home and farm). Baltimore, MD: The Williams and Wilkins Co, p. 90–94.
*Goldfrank LR, Weisman RS, Flomenbaum NE, 1990. Goldfrank’s toxicologic emergencies. 4th ed. Norwalk, CT: Appleton and Lange, 760–768.
Gollhausen R, Klingman AM. 1985. Effects of pressure on contact dermatitis. Am J Ind Med 8(4-5):323–328.4073029
*Goodwin SR, Berman LS, Tabeling BB, 1988. Kerosene aspiration: Immediate and early pulmonary and cardiovascular effects. Vet Human Toxicol 30(6):521–524.
Gordon DC Jr, Prouse NJ. 1973. The effects of three soils on marine phytoplankton photosynthesis. Mar Biol (Berlin) 22(4):329–333.
Green DO. 1977. Intravenous energine: A case report. Clin Toxicol 10(3):283–286.862361
Griest WH, Ho CH, Guerin MR, 1986. Comparative toxicity of crude and refined coal liquids and analogous petroleum products: II. Chemical characterization. Prepared Papers of the American Chemical Society, Division of Fuel Chemistry 31(2)189–195.
Griffin JW. 1954. Hydrocarbon pneumonia following furniture polish ingestion. J Pediatr 45:13–26.13175076
*Gunster DG, Bonnevie NL, Gillis CA, 1993a. Assessment of chemical loadings to Newark Bay, New Jersey from petroleum and hazardous chemical accidents occurring from 1986 to 1991. Ecotoxicol Environ Saf 25(2):202–213.7682504
*Gunster DG, Gillis CA, Bonnevie NL, 1993b. Petroleum and hazardous chemical spills in Newark Bay, New Jersey, USA from 1982 to 1991. Environ Pollut 82(3):245–253.15091773
Gupta P, Singh R, Murali M, 1992b. Kerosene oil poisoning. A childhood menace. Indian Pediatric 29(8):979–984.
Gupta P, Singh R, Murali M, 1992b. Prognostic score for kerosene oil poisoning. Indian Pediatric 29(9):1109-l 112.
Gustavsson P, Evanoff B, Hogstedt C. 1993. Increased risk of esophageal cancer among workers exposed to combustion products. Arch Environ Health 48(4):243–245.8357273
Haas JW, Buchanan MV, Wise MB. 1988. Differentiation of polycyclic aromatic hydrocarbons using a multimode ionization gas chromatographic detector. J Chromatogr Sci 26(2):49–54.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: WB Saunders Company, Harcourt Brace Jovanovich, Inc., 1182–1185.
Hadder G, RM D. 1991. Navy mobility fuels forecasting system report: Navy fuel production in the year 2000. Oak Ridge National Lab Department of Energy, Washington DC.
Haley TJ. 1987. Solvents and chemical intermediates. In: Haley TJ, Berndt WO, eds. Handbook of toxicology. Washington, DC: Hemisphere Publishing Corporation, 504–554.
Hammerle RH, Pierson WR. 1974. Elemental composition of the aerosol in Pasadena, California. Prepared Papers of the American Chemical Society, Division of Environmental Chemistry, National Meeting, Los Angeles, CA, March 30-April 5, 1974, 14(1):285–286.
Hammond SK, Shatkin J. 1990. The use of a laser light scattering detector to determine the mass extractable in organic solvents [Abstract]. Abs Pap Am Chem Sot 199(1-2):123.
*Hara K, Kageura M, Hieda Y, 1988. Application of wide-bore capillary gas chromatography to analyze volatile compounds in body fluids. Jpn J Legal Med 42(2):142–146.
Haraprasad V, Dave JM. 1989. Emission patterns of unvented combustion devices burning liquid and gaseous fuels. In: Proceedings of the ASHRAE/SOEH Conference San Diego California, April 17-20, 1989. Atlanta, GA: American Society of Heating, Refrigerating, and Air-Conditioning Engineers, Inc., 255–262.
Harris VJ, Brown R. 1975. Pneumatoceles as a complication of chemical pneumonia after hydrocarbon ingestion. An J Roentgenol Radium Ther Nucl Med 125(3):531–537.
Hart L, Cobaugh D, Sean B, 1991. Successful use of extracorporeal membrane oxygenation ecmo in the treatment of refractory respiratory failure secondary to hydrocarbon. Vet Hum Toxicol 33(4):361.
Hase A, Lin PH, Hites RA. 1976. Analysis of complex polycyclic aromatic hydrocarbon mixtures by computerized GC-MS. In: Freudenthal R, Jones PW, eds. Carcinogenesis: A comprehensive survey. Volume 1: Polynuclear aromatic hydrocarbon chemistry, metabolites, and carcinogenesis. New York, NY: Raven Press, 435–442.
Hass U, Ladefoged 0. 1985. [Deodorized kerosene: Nordic expert group for documentation of occupational exposure limits.] Arbete och Halsa 24:1–40. (Swedish).
Hawthorne AR, Gammage RB, Dudney CS, 1985. Indoor air quality of forty East Tennessee homes. Washington, DC: Tennessee University, Knoxville Department of Energy.
*HAZDAT. 1992. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. February 1992.
Heath JS, and Koblis K. 1993. Review of chemical physical and toxicological properties of components of total petroleum hydrocarbons. Journal of Soil Contamination 2(l): 125.
Henderson TR, Li AP, Royer RE, 1981. Increased cytotoxicity and mutagenicity of diesel fuel after reaction with NO_2_. Environ Mutagen 3:21l-220.
*Herbes SE, Whitley TA. 1983. Characterization and toxicity of water-soluble photooxidants produced during irradiation of coal liquids by sunlight. Environmental Pollution (Ser B) 6(3):221–240.
Hersh S, Piper BF, Mormile DJ, 1981. Emission characterization of SRC-II fuel oil fired in a utility boiler. In: Proceedings of Governor’s Conference on expanding the use of coal in New York State: Problems and issues, Albany, New York, May 21-22, 1981. New York, NY: Research Foundation of the State University of New York, 323–329.
Hirota Y, Tadeshita S, Kataoka K, 1992. Individual and environmental characteristics related to influenza-like illness among children: A school-based case-control study. Nippon Eiseigaku Zasshi 47(2):587–599.1513053
Holland JM, Rahn RO, Smith LH, 1979. Skin carcinogenicity of synthetic and natural petroleums. J Occup Med 21(9):614–618.490222
Holland JM, Larimer FW, Rao TK, 1984. The distribution of dermal tumorigens in coal liquids: Relationship of tumorigenicity and microbial mutagenicity. J Appl Toxicol 4( 3): 117–123.6379026
Honickey RE, Osborne JS, Akpom CA. 1985. Symptoms of respiratory illness in young children and the use of wood-burning stoves for indoor heating. Pediatrics 75(3):587–593.3975129
*HSDB. 1991. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program. October 1, 1991.
Huff JE, McConnell EE, Haseman JK, , 1988. Carcinogenesis studies results of 398 experiments on 104 chemicals from the U.S. National Toxicology Program. In: Maltoni C, Selikoff IJ, eds. Annals of the New York Academy of Sciences, Volume 534. Living in a chemical world: Occupational and environmental significance of industrial carcinogens. New York, NY: New York Academy of Sciences, l-30.
Huxtable KA. 1964. Experimental furniture polish pneumonia in rats. Pediatrics 34:228–235.14211083
Hyatsu H, Adashi M. 1991. Mutagenicity of tetranitromethane a case difficult to obtain reproducible results in the ames test. Mutation Research 252(1):88.
*IARC. 1989. IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 45: Occupational exposures in petroleum refining: Crude oil and major petroleum fuels. Lyon, France: World Health Organization, International Agency for Research on Cancer.
*Ingram A, King D, Grasso P, 1993. The early changes in mouseskin following topical application of a range of middle distillate oil products. Journal of Applied Toxicology 13(4):247–257.8376725
Jacobziner H, Raybin HW. 1963. Accidental chemical poisonings: Kerosene and other petroleum distillate poisonings. NY State J Med 63:3428–3430.
Jaeger RW, DeCastro F, Blair J, 1978. The brain in hydrocarbon intoxication. Vet Hum Toxicol 20(2):103
Jayaraman V, Ramakrishnan K, Davies M. 1993. Burns in madras india: An analysis of 1368 patients in 1 year. Burns 19(4):339–344.8357482
*Jee SH, Wang JD, Sun CC, 1985. Prevalence of probable kerosene dermatoses among ballbearing factory workers. Stand J Work Environ Health 12(1):61–65.
Johnson F, Sinha S. 1993. Deliberate self-harm by means of kerosene fire by women in Papua New Guinea. Papua New Guinea Medical Journal 36(1):16–21.8266728
*Jones JG. 1977. The long term effects of kerosine pollution on the microflora of a moorland soil. J Appl Bacterial 43(1):123–128.
Jones JG, Knight M, Byrom JA. 1970. Effect of gross pollution by kerosine hydrocarbons on the microflora of a moorland soil. Nature 227(263):1166.5451123
Joubert PH. 1990. Poisoning admissions of black South Africans. J Toxicol Clin Toxicol 28(1):85–94.2381025
*Kainz RJ, White LE. 1984. Depressant effects associated with the inhalation of uncombusted diesel vapor. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modern environmental toxicology. Volume VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc.
Kamamoto T, Matsumo K, Arashidani K, 1993. Personal exposure to nitrogen dioxide from indoor heaters and cooking stoves, Arch Environ Contam Toxicol 25(4):534–533.8239719
Kamat S, Patil J, Gregart J, 1992. Air pollution related respiratory morbidity in central and north -eastern Bombay. J Assoc Physicians India 40(9):588–593.1308013
Kaminski M, Starek A, Plewa A. 1988. [Protective effect of phenobarbital in liver injury by kerosine hydrocarbons in rats.] Folia Med Cracov 29(1-2):87–98. (Polish)3255659
*Kaplan R, Brandt-Rauf P, Azley J, 1993. Residential releases of number 2 fuel oil a contributor to indoor air pollution. American Journal of Public Health 83(1):84–88 8417613
*Karl D. 1992. The grounding of the bahia paraiso microbial ecology of the 1989 Antarctic oil spill. Microbial Ecology 24( 1):77–89.24193041
*Kawahara FK, Fiutem RA, Silvus HS, 1983. Development of a novel method for monitoring oils in water. Anal Chim Acta 151(2):315–327
Kawai A, Goto S, Endo O, 1991. Mutagenicity test for gaseous and vaporous components of combustion exhausts. Mutation Research 252(1):93.
Keen TE B. 1968. The effect of petroleum distillates on lung surfactant. Aust Paediat J 4(4):229–235.
Keenan RR, Cole SB. 1982. A sampling and analytical procedure for skin-contamination evaluation. Am Ind Hyg Assoc J 43(7):473–476.7124621
Kennicutt M, Sweet S. 1992. Hydrocarbon contamination of the antarctic peninsula III. The bahia paraiso two years after the spill. Marine Pollution Bulletin 25(9-12):303–306.
*Kennicutt M, McDonald T, Denoux G, 1992a. Hydrocarbon contamination of the antarctic peninsula 1. Arthur harbor subtidal sediments. Marine Pollution Bulletin 24( 10):499–506.
*Kennicutt M, McDonald T, Denoux G, 1992b. Hydrocarbon contamination of the antarctic peninsula 2. Arthur harbor intertidal and subtidal limpets (nicella-concinna). Marine Pollution Bulletin 24(10):506–511.
Kilmar V. 1991. Accidental poisoning in southwest Maharashtra India. Indian Pediatr 28(7):731–735.1800345
*Kimura K, Nagata T, Hara K, 1988. Gasoline and kerosene components in blood: A forensic analysis. Hum Toxicol 7(4):299–305.3410478
*Kimura K, Nagata T, Kudo K, 1991. Determination of kerosine and light oil components in blood. Biol Mass Spectrom 20(8):493–497.1768706
Kinetic Labs, Inc. 1992. Study of Recovery from oil spill on the rocky intertidal coast of Washington. KLI-R-92-14ÔCS/MMS-92/0072 Minerals Management Service, Camarillo, CA Pacific OCS Region.
Kinnes G, Kawamoto M. 1992. Health hazard evaluation report HETA 89-374-2197, Exxon baytown refinery Baytown, Texas. National Institute for Occupational Safety and Health, Cincinnati, MAR 92:17.
Kinouchi T, Nishifuji K, Tsutsui H, 1988. Mutagenicity and nitropyrene concentration of indoor air particulates exhausted from a kerosene heater. Jpn J Cancer Res 79(1):32–41.3128503
Kissoon N, Vidyasagar D. 1991. Poisoning. Indian Journal of Pediatrics 58(4):431–438.1686873
Kitto M. 1993. Trace-element patterns in fuel oils and gasolines for use in source apportionment. Air & Waste 43(10):1381–1388.
Kleinmen M, Bhalla D, McClure B. 1993. Effects of inhaled fine particles and ozone on pulmonary macrophages and epithelia. Inhal Toxicol 5(4):371.
Knave B, Mindus P, Struwe G. 1979. Neurasthenic symptoms in workers occupationally exposed to jet fuel. Acta Psychiatr Stand 60:39–49.
*Knave B, Olson BA, Elofson S, 1978. Long term exposure to jet fuel: II. A cross-sectional epidemiologic investigation on occupationally exposed industrial workers with special reference to the nervous system. Stand J Work Environ Health 4:19–45.
Koch EM W, Ott R, Koehler CO. 1986. [Age-related differences in pharmacological activities of corticosteroid tropicals.] Arzneim-Forsch 36(2):1540–1544. (German)3814215
Koo LC, Lee N, Ho JH. 1983. Do cooking fuels pose a risk for lung cancer?: A case-control study of women in Hong Kong. Ecol Dis 2(4):255–265.6681156
*Koutrakis P, Briggs S, Leaderer B. 1992. Source apportionment of indoor aerosols in Suffolk and onondaga counties new York. Environ Sci Technol 26(3):521–527.
Krahn M, Ylitalo G, Buzitis J, et ul. 1993. Rapid high-performance liquid-chromatographic methods that screen for aromatic-compounds in environmental-samples. Journal of Chromatography 642( l-2): 15–32.
Kryuchkov V. 1991a. Extreme anthropogenic loads and the state of ecosystems in the north. Ekologiya 0(3):28–40.
Kryuchkov V. 1991b. Maximal anthropogenic loading and condition of northern ecosystems. Soviet Journal of Ecology 22(3):155–166.
Kryuchkov V. 1993. Extreme anthropogenic loads and the northern ecosystem condition. Ecological Applications 3(4):622–630.27759284
Kumar A, Mohan M. 1986. Kerosene poisoning. Indian Pediatr 23:178–179.3666902
Lacey P, Lestz S. 1991. Failure analysis of fuel injection pumps from generator sets fueled with Jet A-1. Southwest Research Int San Antonio, TX. Belvoir Fuels and Lubricants Research Facility.
*Lam WK, Du YX. 1988. Environmental inhaled agents and their relation to lung cancer. In: Loke, ed. Pathophysiology and treatment of inhalation injuries: Lung Biology in Health and Disease, Vol. 34. New York, NY: Marcel Dekker, 423–451.
*Lamey SC, Hesbach PA, White KD. 1991. Liquid fuel analyses using high-performance liquid chromatography and gas chromatography-mass spectroscopy. Energy and Fuels 5:222–226.
*Larson RA, Bott TL, Hunt LL, 1979. Photooxidation products of a fuel oil and their antimicrobial activity. Environmental Science and Technology 13(8):965–969.
*Larson RA, Hunt LL, Blankenship DW. 1977. Formation of toxic products from a #2 fuel oil by photooxidation. Environmental Science and Technology 11(5):492–496.
Lashley P, St. John M. 1991. A review of accidental-poisoning in barbados - A new perspective( 1981-1985). Annuals of Tropical Paediatrics 11(2):149–153.
*Latimer JS, Hoffman EJ, Hoffman G, 1990. Sources of petroleum hydrocarbons in urban runoff. J Water Air Soil Pollut 52(1-2):1–21.
Laurent P, Guyotjeannin C, Thin D. 1967. [Apropos of occupation diseases of workers who clean fuel oil boilers (2).] Arch Ma1 Prof 28(10):789–792. (French)
Laursen H, Hansen A, Sheardown M. 1993. Cerebrovascular permeability and brain edema after cortical photochemical infarcts in the rat. Acta Neuropathologica 86(4):378–385.8256589
Lazner J. 1970. Summer poison hazards for young children. Med J Aust 2(23):1098.5491088
Leaderer BP, Zagraniski RT, Berwick M, 1986. Assessment of exposure to indoor air contaminant from combustion sources: Methodology and application. Am J Epidemiol 124(2):275–289.3088984
Leary J, Biemann K, Braun A, 1984. Chemical and toxicologic characterization of No. 2 fuel oil and its combustion products at different smoke numbers. American Chemical Society (ACS), 187th National Meeting 8-13 Apr 1984 St. Louis, MO.
Leary JA, Bieman K, Lafleur AL, 1987. Chemical and toxicological characterization of residential oil burner emissions: I. Yields and chemical characterization of extractables from combustion of no. 3 fuel oil at different Bacharach smoke numbers and firing cycles. Environ Health Perspect 73:223–234.3665865
Lebowitz H, Brusick D, Matheson D, 1979. Commonly used fuels and solvents evaluated in a battery of short-term bioassays [Abstract]. Environ Mutagen 1:172–173.
*Lee L, Agwall M, Delfino J, 1992. Partitioning of Polycyclic aromatic-hydrocarbons from diesel fuel imo water. Environmental Science and Technology 26(11):2104–2110.
Lee ML, Prado GP, Howard JB, 1977. Source identification of urban airborne polycyclic aromatic hydrocarbons by gas chromatographic mass spectrometry and high resolution mass spectrometry. Biomed Mass Spectrom 4(3):182–185.890079
*Lesnik R, Kligman L, Kligman A. 1992. Agents that cause enlargement of sebaceous glands in hairless mice. Arch Dermatol Res 284(2):100–105.1610208
Lewis SC, King RW, Cragg ST, 1984. Skin carcinogenic potential of petroleum hydrocarbons: II. Crude oil, distillate fractions and chemical class subfractions. In: MacFarland HN, Holdsworth CE, MacGregot JA, , eds. Advances in modern environmental toxicology. Vol. VI: Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc.
Lewtas J. 1993. Complex mixtures of air pollutants: Characterizing the cancer risk of polycyclic organic matter. Environmental Health Perspectives 100:211–218.8354169
Lewtas J, Claxton L, Mumford J, 1993. Bioassay of complex mixtures of indoor air pollutants. IARC Sci Pub1 109:85–95.
*Lieberman S, Inman S, Theriault G. 1993. Laser-induced fluorescence over optical fibers for real time in situ measurement of petroleum hydrocarbons in seawater. Naval Command, Control and Ocean Surveillance Center San Diego, Ca.
Lillienberg L, Hogstedt B, Jarvholm B, 1992. Health effects at tank cleaners. American Industrial Hygiene Association 53(6):375–380.
*Lindquist R, Nilsson B, Eklund G, 1991. Acute leukemia in professional drivers exposed to gasoline and diesel. Eur J Haematol 47(2):98–103.1889488
Lipfert F, DePhillips M, Moskowitz P. 1992. Air toxics from heavy oil production and consumption. Brookhaven National Lab Lipton, NY.
Lipfert F, DePhillips M, Moskowitz P. 1992. Air toxics from heavy oil production and consumption. Brookhaven National lab Department of Energy, Washington DC.
Lewtas J. 1989. Toxicology of complex mixtures of indoor air pollutants. Annu Rev Pharmacol and Toxicol 29:415–439.2658776
*Liss-Suter D, Villaume JE, Goldstein FJ. 1978. A literature review - problem definition studies on selected toxic chemicals. Volume 8: Environmental aspects of diesel fuels and fog oils SGF no. 1 and SGF no. 2 and smoke screens generated from them. Philadelphia, PA: Franklin Institute Research Laboratories. Final report. Contract no. DAMD 17-77-C-7020. AD A056021.
*Litovitz T, Greene AE. 1988. Health implications of petroleum distillate ingestion, Occup Med 3(3):555–568.2900559
*Litz N, Blume H-P. 1989. [Behaviour of organic chemicals in soils and a prognosis after a contamination.] Z Kulturtechnik Landentwicklung 30(6):355–364. (German)
Lizasa T, Moniki S, Bauer B, 1993. Invasive tumors derived from xenotransplanted, immortalized human cells after in vivo exposure to chemical carcinogens. Carcinogenesis 14(9):1789–1794.8403201
*Lock S, Dalbey W, Schmoyer R, 1984. Chemical characterization and toxicologic evaluation of airborne mixtures: Inhalation toxicology of diesel fuel obscurant aerosol in Sprague-Dawley rats. Final report, phase 3: Subchronic exposures. Oak Ridge, TN: Oak Ridge National Laboratory. ORNL/TM-9403.
Lockard JM, Prater JW, Viau CJ, 1982. Comparative study of the genotoxic properties of Eastern and Western U.S. shale oils, crude petroleum, and coal-derived oil. Mutat Res 102(3):221–235.6755232
Lollar RM. 1980. Are carcinogens a chronic health hazard in the tannery workplace? JALCA 75:510–525.
Lomer C, Teman R, Gosonou I, 1993. Field infection of zonocerus-variegatus following application of an oil-based formulation of metarhizium-flavoviride conidia. Biocontrol Science and Technology 3(3):337–346.
Lupulescu A. 1973. Electron microscopic autoradiography of 3H-kerosene in human epidermis: 13th annual meeting of American Society for Cell Biology. Journal of Cell Biology 59(2).
*Lupulescu AP, Birmingham DJ. 1975. Effect of lipid solvents on protein, DNA, and collagen synthesis in human skin: An electron microscopic autoradiographic study. J Invest Dermatol 65(5):419–422.1194707
*Lupulescu AP, Birmingham DJ. 1976, Effect of protective agent against lipid-solvent-induced damages: Ultrastructural and scanning electron microscopial study of human epidermis. Arch Environ Health 31(1):33–36.128331
*Lupulescu AP, Birmingham DJ, Pinkus H. 1973. An electron microscopic study of human epidermis after acetone and kerosene administration. J Invest Dermatol 60(1):33–45.4684159
*MacKerron CB, Kiesche ES. 1988. After the Ashland spill, more regulations? Chemical Week 142(1,2):19–20.
*MacNamara BGP. 1968. The treatment of poisoning in children. West Indian Med J 17(3):166–171.5732761
MacNaughton MG, Uddin DE. 1984. Toxicology of mixed distillate and high-energy synthetic fuels. Adv Mod Env Toxicol 7:121–132.
Macys D, Carpenter R, Risher J, 1992. Results of a workshop on health effects of crude oil exposures related to operation desert storm Final report 14-15 Feb. 1991. MainTech Environmental Technology, Inc Dayton OH.
*Mahdi AH. 1988. Kerosene poisoning in children in Riyadh. J Trap Pediatr 34(6)316–318.
Mahlman M. 1991. Dangerous and cancer-causing properties of products and chemicals in the oil refining and petrochemical industry, part XII. Human health and environmental hazards. In Mehlman MA, ed., Advances in Modern Environmental Toxicology, Vol XIX Health and Risks from Exposure to Complex Mixtures and Air Toxic Chemicals, Princeton Scientific Publishing CO, Inc., Princeton, New Jersey, 99– 116.
Maier H, Devries N, Show G. 1991. Occupational factors in the aetiology of head and neck cancer. Clin Otolaryngol Allied Sci 16(4):406–412.1934560
*Majeed HA, Bassyouni H, Kalaawy M, 1981. Kerosene poisoning in children: A clinicoradiological study of 205 cases. Ann Trop Pediatr 1(2):123–130.
*Mann MD, Pirie DJ, Wolfsdorf J. 1977. Kerosene absorption in primates. J Pediatr 91(3):495–498.408472
*Martin JH, Siebert AJ, Loehr RC. 1991. Estimating oil and grease content of petroleum-contaminated soil. Journal of Environmental Engineering 117(3):291–299.
Mattie DR, Alden CL, Newell TK, 1991. A 90-day continuous vapor inhalation toxicity study of JP-8 jet fuel followed by 20 or 21 months of recovery in Fischer 244 rats and C57BL/6 mice. Toxicol Pathol 19(2):77–87.1771370
McGill WB, Rowe11 MJ. 1980. Determination of oil content of oil contaminated soil. Sci Total Environ 14:245–253.
McKee R, Freeman J. 1993. Dermal carcinogenicity studies of petroleum-derived materials. In Wang RGM, Knaak JB, Maiback HI, eds., Health Risk Assessment: Dermal and Inhalation Exposure and Absorption of Toxicants CRC Press, Ann Arbor MI, 263–274.
*McKee RH, Amoruso MA, Freeman JJ, Przygoda RT. 1994. Evaluation of the genetic toxicity of middle distillate fuels. Exxon Biomedical Services, Inc., East Millstone, NJ.
McKee RH, Kapp RW Jr, Ward DP. 1985. Evaluation of the systemic toxicity of coal liquefaction-derived materials following repeated dermal exposure in the rabbit. J Appl Toxicol 5(6):345–351.4078215
McKee RH, Nicolich MJ, Scala Ra, 1990. Estimation of epidermal carcinogenic potency. Fundamental and Applied Toxicology. 15:230–328.
McKee RH, Pasternak SJ, Traul KA. 1987a. Developmental toxicity of EDS recycle solvent and fuel oil. Toxicology 46(2):205–215.3672532
*McKee RH, Plutnick RT, Przygoda RT. 1989. The carcinogenic and initiating and promoting properties of a lightly refined paraffinic oil. Fundam Appl Toxicol 12(4):748–756.2663578
McKee RH, Plutnick RT, Traul KA. 1987b. Assessment of the potential reproductive and subchronic toxicity of EDS coal liquids in Sprague-Dawley rats. Toxicology 46(3):267–280.3672535
Melia RJ W, Chinn S, Rona RJ. 1990. Short communication: Indoor levels of NO_2_ associated with gas cookers and kerosene heaters in inner city areas of England. Atmos Environ 24B(1):177–180.
*Midkiff CR Jr, Washington WD. 1972. Gas chromatographic determination of traces of accelerants in physical evidence. J Assoc Off Anal Chem 55(4):840–845.
*Mille G, Guiliano M, Reymond H, 1985. Analysis of hydrocarbons by Fourier transform infrared spectroscopy. Int J Environ Anal Chem 21(3):239–260.
Millner GC, Nye AC, James RC. 1992. Human health based soil cleanup guidelines for diesel fuel No. 2. In: Kostecki PT, Calabrese EJ. Contaminated Soils-Diesel Fuel Contamination. Lewis Publishers. Ann Arbor, MI.
Mintz AA. 1966. Furniture polish intoxication. South Med J 59:1010–1014.5919764
Mishad MM. 1969. Kerosene poisoning. Ain Shams Medical Journal 20(2)125–128.
Mitsue R, Okuyama S, Fujimura Y. 1991. Determination of the blend composition ratio of gasoline to kerosene by multivariate analysis. Bunseki Kagaku 40:389–394.
*Molden A. 1992. Collision results in fuel-oil spill in South-African waters. Marine Pollution Bulletin 24(6):281.
Mijller L, Torndal UB, Eriksson LC, 1989. The air pollutant 2-nitrofuran as initiator and promoter in a liver model for chemical carcinogenesis. Carcinogenesis 10(3):435–440.2924391
Mommsen S, Aagard J. 1984. Occupational exposures as risk indicator of male bladder carcinoma in a predominantly rural area. Acta Radio1 23(2-3):147–152.
Moore WS, Hyland JL, Melzian BD, 1978. Technique for removal of dissolved and dispersed hydrocarbons from bioassay effluents. Environ Sci Technol 12(5):595–596.
*Morrison I, Sprague P. 1976. Kerosene pneumonia: Its incidence in Perth and case history of a recent fatality. Australas Radio1 20(2):118–121.
*Morrison H, Semenciw R, Morrison D, 1992. Brain cancer and farming in western Canada. Neuroepidemiology 11:267–276.1337947
*Morrison H, Semenciw R, Wilkins K, 1994. Non-Hodgkin’s lymphoma and agricultural practices in the prairie provinces of Canada. Stand J Work Environ Health 20(1):42–47.
Morrow P, Muhle H, Memelstein R. 1991. Chronic inhalation study findings as a basis for proposing a new occupational dual exposure limit. J Am Coll Toxicol 10(2):279.
*Mosconi G, Migliori M, Greco V, 1988. Kerosene “bums”: A new case. Contact Dermatitis 19(4):314–315.3219847
*Mumford JL, Williams RW, Walsh DB, 1991. Indoor air pollutants from unvented kerosene heater emissions in mobile homes: Studies on particles, semivolatile organics, carbon monoxide, and mutagenicity. Environ Sci Technol 25(10):1732–1738.
Muralidhara Krishnakumari MK. 1980. Acute oral toxicity of some petroleum fractions used in pesticidal formulations to albino rats [Abstract]. Indian J Biochem Biophys 18(4):149–150.
“Muralidhara, Krishnakumari MK, Ramesh HP, 1982. Toxicity of some petroleum fractions used in pesticidal emulsions to albino rats. J Food Sci Technol 19(6):260–262.
*Mushrush G, Mose D, Sullivan K. 1994. Soil vapor and ground water analysis from a recent oil spill. Bulletin of Environmental Contamination and Toxicology 52(1):31.8130414
Narasimhan MJ, Ganla VG. 1967. Experimental studies on kerosene poisoning. Acta Pharmacol Toxicol 25(2):214–224.
*NAS/NRC. 1989. Biological markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
*NATICH. 1991. National Air Toxics Information Clearinghouse. Data base report on state, local, and EPA air toxics activities. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Washington, DC. August 13, 1991.
Nethercott JR, Lawrence M. 1983. The effect of the guinea pig maximization protocol on the irritant response to deodorized kerosene: The excited skin syndrome. Contact Dermatitis 9(6):439–443.6653100
*Newton J, Rothman B, Walker F. 1991. Separation and determination of diesel contaminants in various fish products by capillary gas chromatography. Journal of the Association of Official Analytical Chemists 74(6):968–990.
*Ng RC, Darwish H, Stewart DA. 1974. Emergency treatment of petroleum distillate and turpentine ingestion. Can Med Assoc J 111:537–538.4153346
Nhachi C, Kasilo 0. 1994. Household chemicals poisoning admissions in Zimbabwe main urban centers. Human and Experimental Toxicology 13(2):69–72.7908812
Nicholson A. 1975. Quantitative analysis of fuel oils and gasoline in drinking water by gas chromatography. First chemical congress of the north american continent [abst]. American Chemical Society Washington, DC.
Nieman GF, Clark WR, Wax SD, 1980. The effect of smoke inhalation on pulmonary surfactant. Ann Surg 191(2):171–181.6892674
NIOSH. 1975. Environmental injury and repair of epidermis. Cincinnati, OH: National Institute for Occupational Safety and Health.
*NIOSH. 1992. NIOSH pocket guide to chemical hazards. Cincinnati, OH: National Institute for Occupational Safety and Health. DHHS(NIOSH) publication no. 90-l 17.
*NIOSH. 1994. Manual of analytical methods. 4th ed. Eller PM, ed. Cincinnati, OH: National Institute for Occupational Safety and Health. Publication no. 94-113, Method 1550.
Nitschke IA, Traynor GW, Wadach JB, 1985. Indoor air quality, infiltration and ventilation in residential buildings. Albany, NY: New York State Energy Research and Development Authority. Document no. PB89-165500.
*Noa M, Illnait J. 1987a. Changes in the aorta of guinea pigs exposed to kerosene. Acta Morphologica Hungarica 35(1-2):59–69.2449038
Noa M, Illnait J. 1987b. Induction of aortic plaques in guinea pigs by exposure to kerosene. Arch Environ Health 42:3 l-36.
Noa M, Sanabria J. 1984. Tracheal ultrastructure in kerosene treated guinea pigs: A preliminary report. Allergol Immunopathol 12( 1):33–36.
Noa M, Illait J, Gonzalez R. 1985. Cytologic and biochemical changes in pulmonary washings of guinea pigs exposed to kerosene. Allergol Immunopathol 13(3):193–196.
*NOAA. 1982. Effects from residual and no. 2 fuel oils on intertidal infauna recovery rate. Seattle, WA: National Oceanic and Atmospheric Administration, Office of Marine Pollution Assessment. Document no. PB83-152298.
*NOES. 1992. National Occupational Exposure Survey. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Division of Surveillance, Hazard Evaluations and Field Studies.
*Nouri L, Al-Rahim IS. 1970. Kerosene poisoning in children. Postgrad Med .I 46(532):71–75.
*Nouri LA, Sordelli DO, Cerquetti MC, 1983. Pulmonary clearance of Staphylococcus aweus and plasma angiotensin-converting enzyme activity in hydrocarbon pneumonitis. Pediatr Res 17(8):657–661.6310474
*NTP/NIH. 1986. National toxicology program technical report series no. 310: Toxicology and carcinogenesis studies of marine diesel fuel and JP-5 navy fuel in B6C3Fl mice (dermal studies). Research Triangle Park, NC: National Toxicology Program/National Institutes of Health. NIH publication no. 86-2566.
Nussinsovitch M, Amir J, Arsano I. 1992. Chemical pneumonia and dermatitis caused by kerosene. Clinical Pediatrics 31(9):574.1468179
Nylander G, Berg K. 1991. Mutagenicity study of urine from smoking and non-smoking road tanker drivers. Int Arch Occup Environ Health 63(4):229–232.1743763
*OHM/TADS. 1985. Oil and Hazardous Materials/Technical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc. December, 1985.
Ohnishi Y, Kinouchi T, Manabe Y, 1985. Nitro compounds in environmental mixtures and foods. Environ Sci Res 32(4):195–204.
Okamori K, Tanaka S, Hashimoto Y. 1991. Transport of soil particles an pollutants to the ocean and their concentration distribution in the marine atmosphere. A study of marine aerosols collected on board the antarctic observation ship “Shirase”. Nippon Kagaku Kaishi 6:759–765.
*Olson MJ, Johnson JT, Reidy CA. 1990. A comparison of male rat and human urinary proteins: Implications for human resistance to hyaline droplet nephropathy. Toxicol Appl Pharmacol 102:524–536.1690459
*OSHA. 1989a. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA. 1989b. Air contaminants. Occupational Safety and Health Administration. Federal Register 54:2920–2960.
O’Sullivan BP. 1983. Carbon monoxide poisoning in an infant exposed to a kerosene heater. J Pediatr 103(2):249–251.6875719
*Oviatt C, Frithsen J, Gearing J, 1982. Low chronic additions of no. 2 fuel oil: Chemical behavior, biological impact and recovery in a simulated estuarine environment. Mar Ecol Prog Ser 9:121–136.
Oxenford JL, McGeorge LJ, Jenniss SW. 1989. Determination of practical quantitation levels for organic compounds in drinking water. J Am Water Works Assoc 81(4):149–154.
Palma-Carlos AG. 1975. [Diseases caused by inhalation of organic dusts.] Allergol Immunopathol 3(5):339–356. (Spanish)
*Panson RD, Winek CL. 1980. Aspiration toxicity of ketones. Clin Toxicol 17(2):271–317.7418363
Papini RP G. 1991. ‘Is all that’s blistered burned?’ . . . a case of kerosene contact burns. Bums 17:415–416.
*Parker GA, Bogo V, Young RW. 1981. Acute toxicity of conventional versus shale-derived JP-5 jet fuel: Light microscopic, hematologic, and serum chemistry studies. Toxicol Appl Pharmacol 57(3):302–317.7222045
*Partanen T, Heikkila P, Hemberg S, 1991. Renal cell cancer and occupational exposure to chemical agents. Scan J Work Environ Health 17(4):231–239.
Patterson A. 1993. Hand dermatitis in a hand cleanser salesman. Contact Dermatitis 28(2):119–120.
Perrone H, Passero MA. 1983. Hydrocarbon aerosol pneumonitis in an adult. Arch Intern Med 143(8):1607–1608.6347114
*Pharr D, McKenzie J, Hickman A. 1992. Fingerprinting petroleum contamination using synchronous scanning fluorescence spectroscopy. Ground Water 30(4):484–489.
Phillips RD, Cockrell BY. 1984. Effect of certain light hydrocarbons on kidney function and structure in male rats. In: Mehlman MA, Hemstreet GP II I, Thorpe JJ, , eds. Advances in modern environmental toxicology: Volume VII. Renal effects of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers.
*Porter HO. 1990. Aviators intoxicated by inhalation of JP-5 fuel vapors. Aviat Space Environ Med 61(7):654–656.2386453
Power A, Mathys G. 1992. Characterization of distillate fuel sediment molecules-functional-group derivatization. Fuel 71(8):903908.
Presley LA. 1979. Evaluation of a portable gas chromatograph for arson analysis: Column selection. Arson Anal News1 3(5):18–34.
Prince R. 1993. Petroleum spill bioremediation in marine environments. Critical Reviews in Microbiology 19(4):217–242.8305136
Puranen A, Matila M. 1992. Exhaust emissions from work machinery in finland. Environ Int 18(5):467–476.
Qaryoute SM. 1984. Skin ulceration induced by kerosene injection. Ann Plast Surg 12(4):361–363.6721395
Ragland KW, Andren AW, Manchester JB. 1985. Emissions from unvented kerosene heaters. Sci Total Environ 46:171–179.4081780
*Rahimtula AD, Payne JF, Martins I. 1982. Hydrocarbon-based oils as inducers of cutaneous aryl hydrocarbon hydroxylase. Toxicol Lett 10(2-3):213–217.7080087
Rahimtula AD, O’Brien PJ, Payne JF. 1984. Induction of xenobiotic metabolism in rats on exposure to hydrocarbon-based oils. Adv Mod Toxicol 6:7 l-79.
Rai UC, Singh TS K. 1980. Cardio-pulmonary changes in mongrel dogs after exposure to kerosene smoke. Indian J Exp Biol 18(11):1263–1266.7216284
Raiyani C, Shah S, Desai N, 1993. Characterization and problems of indoor pollution due to cooking stove smoke. Atmos Environ Part A Gen Top 27(11):1643–1655.
*Rao GS, Pandya KP. 1980. Hepatic metabolism of heme in rats after exposure to benzene, gasoline, and kerosene. Arch Toxicol 46(3-4):313–317.6894534
Rao GS, Kannan K, Goel SK, 1984. Subcutaneous kerosene toxicity in albino rats. Environ Res 35(2):516–530.6510400
*Raymond RL, Hudson JO, Jamison VW. 1975. Assimilation of oil by soil bacteria. Proceeding of the American Petroleum Institute, Refining Department 54:429–455.
*Raymond RL, Hudson JO, Jamison VW. 1976. Oil degradation in soil. Appl Environ Microbial 31(4):522–535.
*Regnier ZR, Scott BF. 1975. Evaporation rates of oil components. Environmental Science & Technology 9(5):469–472.
*Reidenberg MM, Powers DV, Sevy RW, 1964. Acute renal failure due to nephrotoxins. Am J Med Sci 247125–29.
Reish D. 1993. Effects of metals and organic compounds on survival and bioaccumulation in two species of marine gammaridean amphipod, together with a summary of toxicological research on the group. Journal of Natural History 27(4):781–794.
Rice D, Seltenrich C, Spies R, 1993. Seasonal and annual distribution of organic contaminants in marine sediments from elkhom slough moss landing harbor and nearshore monterey bay california. Environmental Pollution 82( 1):79–91.15091802
Ring R, Nelson JD. 1966. Hydrocarbon pneumonitis in rats: Comparison of mineral seal oil, furniture polish, and kerosene toxicities with an evaluation of gastric lavage. Arch Environ Health 13(6):749–752.5924061
Richardson JA, Pratt-Thomas HR. 1951. Toxic effects of varying doses of kerosene administered by different routes. Am J Med Sci 221:531–536.14829453
*Riss A, Schweisfurth R. 1987. [The degradation of fuel oil via denitrification: Effect of nitrate concentration.] Vom Wasser 68: 111–123. (German)
Rissmiller R. 1983. Kerosene heaters: A new burn threat to children. Clin Pediatr 22(3):203.
Ritchie IM, Oatman LA. 1983. Residential air pollution from kerosene heaters. J Air Pollut Control Assoc 33(9):879–880.
Rodriquez de la Vega A, Casaco A, Garcia M, 1990. Kerosene-induced asthma. Ann Allergy 64(4):362–363.2321811
*Rosenblatt D, Montemagno C. 1992. Criteria for evaluating the health risk remaining after bioremediation of a buried mass of diesel fuel No. 2. Department of Energy Washington, DC. Rothman N, Emmett EA. 1988. The carcinogenic potential of selected petroleum-derived products. Occup Med 3(3):475–489.
Roudabush RL, Terhaar CJ, Fassett DW, 1965. Comparative acute effects of some chemicals on the skin of rabbits and guinea pigs. Toxicol Appl Pharmacol 7(4):559–565.5839391
*Rowe LD, Dollahite JW, Camp BJ. 1973. Toxicity of two crude oils and of kerosine to cattle. J Am Vet Med Assoc 162(1):61–66.4683544
*RTECS. 1992. Registry of Toxic Effects of Chemical Substances. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC.
*Runion HE. 1988. Occupational exposures to potentially hazardous agents in the petroleum industry. Occupational Medicine: State of the Art Reviews 3(3):431–444.
Rushton L. 1993. A 39-year follow-up of the U.K. oil refinery and distribution center studies: Results for kidney cancer and leukemia. Environ Health Perspect Supplements 101 (Suppl. 6):77–84.
Ryan PB, Spengler JD, Letz R. 1983. The effects of kerosene heaters on indoor pollutant concentrations: A monitoring and modeling study. Atmos Environ 17(7): 1339– 1345.
Sagai M, Saito H, Ichinose T, 1993. Biological effects of diesel exhaust particles I. In vitro production of superoxide and in vivo toxicity in mouse. Free Radic Biol Med 14(1):37–47.8384149
*Saksena PN. 1969. Kerosine oil poisoning in children. J Indian Med Assoc 52(4):169–171.5771208
Samet JM, Marbury MC, Spengler JD. 1987. Health effects and. sources of indoor air pollution: Part I. Am Rev Respir Dis 136(6):1486–1508.3318602
Sanabria J, Noa M, Casaco A, 1984. [Morphological changes in the respiratory system of guinea pigs after kerosine aerosol administration.] Allergol Immunopathol 12(3):213–215. (Spanish)
*Santhanakrishnan BR, Chithra S. 1978. Accidental kerosene poisoning in infants and children. Indian J Pediatr 45(367):265–273.730290
Sarker AK, Ghosh S, Batik K. 1990. A study of accidental poisoning (in children) in a rural medical college hospital of West Bengal. Indian J Public Health 34(3):159–162.2103925
Salthouse R. 1992. Making Clean Gasoline: The Effect on Jet Fuels. Logistics Management Inst Bethesda, MD.
Sas P, Sharan P, Axena S. 1992. Kerosene abuse by inhalation and ingestion. American Journal of Psychiatry 149(5):710.
Sawhney CP. 1989. Flame burns involving kerosene pressure stoves in India. Bruns 15(6):362–364.
*Sax NI, Lewis RJ Sr. 1989. Dangerous properties of industrial materials. 7th ed. New York, NY: Van Nostrand Reinhold.
Scharf SM, Prinsloo I. 1982. Pulmonary mechanics in dogs given different doses of kerosene intratracheally. Am Rev Respir Dis 126(4)695–700.7125363
Scharf SM, Heimer D, Goldstein J. 1981. Pathologic and physiologic effects of aspiration of hydrocarbons in the rat. Am Rev Respir Dis 124(5):625–629.7305118
*Scherr P, Hutchinson G, Neiman R. 1992. Non-Hodgkin’s GB lymphoma and occupational exposure. Cancer Res 52(19):5503–5509.
Schreiner CA. 1983. Petroleum and petroleum products: A brief review of studies to evaluate reproductive effects. Adv Mod Env Toxicol 3:29–45.
*Schultz TW, Epler JL, Witschi H, 1981. Health effects research in oil shale development. Oak Ridge National Laboratory report no. ORNL/TM-8034. Oak Ridge, TN: Oak Ridge National Laboratory.
Selden A, Ahlborg G Jr. 1991. Mortality and cancer morbidity after exposure to military aircraft fuel. Aviat Space Environ Med 62(8):789–794.1930063
*Semenciw R, Al E. 1993. Multiple myeloma mortality. J of Occup Med 35(6):557–561.8331434
*Sengupta R, Fondekar S, Alagarsamy R. 1993. State of Oil Pollution in the Northern Arabian Sea after the 1991 Gulf Oil Spill. Marine Pollution Bulletin 27:85–91.
Senz G, Pingitore N. 1991. Characterization of hydrocarbon contaminated areas by multivariate statistical analysis: Case studies. Environ Monit Assess 17(2-3):281–302.24233510
Sexton K, Webber LM, Hayward SB, 1986. Characterization of particle composition, organic vapor constituents, and mutagenicity of indoor air pollutant emissions. Environment International 12:351–362.
Sharma V, Ansari M, Razdan R. 1993. Use of kerosene lamp containing synthetic pyrethroids to repel mosquitoes. Indian Journal of Malariology 30(3):169–176.8131884
Shen J, Martha R. 1992. Changes in acute toxicity during on-site bioremediation of soil contaminated by no. 2 fuel oil. 92nd General Meeting of the American Society for Microbiology 92:355.
*Shirkey HC. 1971. Treatment of petroleum distillate ingestion. Mod Treat 8(3):580–592.4941270
Siemiatycki J, Dewar R, Nadon L, 1987. Associations between several sites of cancer and twelve petroleum-derived liquids. Stand J Work Environ Health 13(6):493–504.
Singh H, Chugh J, Shembesh A, 1992. Management of Accidental Kerosene Ingestion. Ann Trop Paediatr 12(1):105–109.1376577
*Singh S, Narang A, Walia BN, 1981. Accidental poisoning in children: Ten years experience. Indian Pediatr 18(3):163–166.7263018
*Skisak C. 1991. The role of chronic acanthosis and subacute inflammation in tumor promotion in CD-l mice by petroleum middle distillates. Toxicol Appl Pharmaol 109(3):399–411.
Skyberg K, Ronneberg A, Kamoy JI, 1986. Pulmonary fibrosis in cable plant workers exposed to mist and vapor of petroleum distillates. Environ Res 40(2):261–273.3732201
Smuin D, Crutcher J. 1991. Applicability of environmental laws to the remedial investigation and cleanup of a site at Naval Air Station Fallon, Nevada. Hazrap: Navy remedial action investigation feasibility study. Oak Ridge National Laboratory TN.
*Soczo ER, Staps JJM. 1988. Review of biological soil treatment techniques in the Netherlands. In: Wolf K, van den Brink WJ, Colon FJ, eds. Contaminated soil ‘88: Second International Netherlands Organization for Applied Scientific Research/Federal Ministry of Research and Technology Conference, Hamburg, West Germany, April 11-15, 1988. Boston, MA: Kluwer Academic Publishers, 663–670.
Squire Al. E. 1978. Pathology of Laboratory Animals. Springer-Verlag, NY, 1068–1069.
*St. John MA. 1982. Kerosene poisoning in children in Barbados. Ann Trop Paediatr 2(1):37–40.6186189
Stainken D. 1975. Preliminary observations on mode of accumulation of no. 2 fuel oil by soft shell clam. 1975 Conference on Prevention and Control of Oil Pollution San Francisco, California.
Starek A. 1980a. [The influence of kerosene hydrocarbons on the activity of acid hydrolases of lymphocytes in rats.] Folia Med Cracov 22(3-4):385–392. (Polish)7026388
Starek A. 1980b. [The influence of kerosene hydrocarbons on the activity of acid hydrolases of neutrophils and serum in rats.] Folia Med Cracov 22(3-4):375–384. (Polish)7026387
Starek A. 1983. [Some biological effects of chronic exposure to kerosine hydrocarbons.] Med Pr 34(5-6):451–454. (Polish)
Starek A. 1988. [The effect of kerosene hydrocarbons on microsomal monooxygenases activity in rat liver.] Folia Med Cracov 29(3-4):161–170. (Polish)3267613
Starek A, Czosnek-Dabros E. 1982. [Functional alterations in the liver and kidneys of rats following acute poisoning with kerosine hydrocarbons and Mentor 28.1 Bromatol Chem Toksykol 15(4):259–265. (Polish)
Starek A, Golba W. 1984. [Determination of kerosene vapors in air by gas chromatography.] Med Pr 35(5):373–378. (Polish)6530955
Starek A, Kaminski M. 1981. [Toxicity of certain petroleum derivatives used as dielectrics in electromachining: IV. Morphologic and cytoenzymic changes in lungs and disorders of acid-base equilibrium in rats chronically exposed to kerosene hydrocarbons.] Med Pr 32(2):69–81. (Polish)6458751
Starek A, Kaminski M. 1982. [Toxicity of certain petroleum derivatives used as dielectrics in electromachining: V. Morphological, cytoenzymic, and biochemical changes in the liver of rats chronically exposed to kerosine hydrocarbons.] Med Pr 33(5-6):239–253. (Polish)6304448
*Starek A, Vojtisek M. 1986. Effects of kerosene hydrocarbons on tissue metabolism in rats. Pol J Pharmacol Pharm 38(5-6):461–469.3575166
Starek A, Fiema L, Cembala D, 1975. [Comparing toxicity of certain oil products used as dielectrics in electroerosive working: I. Acute and subacute toxicity.] Med Pr 26(3):219–230. (Polish)
Starek A, Plewka A, Kaminski M, 1988. [The effect of kerosene hydrocarbons and phenobarbital on the microsomal electron transport chain in rat liver.] Folia Med Cracov 29(1-2):49–57. (Polish)3255657
*State of Alaska. 1989. Alaska water quality standards. Juneau, AL: Alaska Administrative Code, Water Quality Standards, Amended 12/89. Alaska Title 18, Chapter 70.
*State of Arkansas. 1991. Regulation no. 2 as amended water quality standards for surface waters of the State of Arkansas. Little Rock, AK: Water Quality Standards for Surface Waters of the State of Arkansas.
*State of Florida. 1992. Florida Water Quality Standards 1992. Tallahassee, FL: Florida Water Quality Standards 17.-3.
*State of Nebraska. 1990. Nebraska water quality standards 1990. Lincoln, NE: Nebraska Water Quality Standards for Surface Waters of the State, revised effective 8/29/88. Nebraska State, Title 117.
*State of New York. 1989. New York public drinking water standards. Albany, NY: New York Public Drinking Water Standards, Code Revision.
*State of South Dakota. 1989. South Dakota water quality standards 1989. Bismarck, SD: South Dakota Surface Water Quality Standards, 2/89. Chapter 74:04:02.
*State of Wyoming. 1990. Wyoming water quality rules and regulations. Cheyenne, WY: Wyoming Water Quality Standards. Cheyenne, WY: Wyoming Department of Environmental Quality, Water Quality Standards for Wyoming Surface Waters, Chapter I.
Staudemayer H, Selner J, Buhr M. 1993. Double-blind provocation chamber challenges in 20 patients presenting with multiple chemical sensitivity. Regul Toxicol Pharmacol 18(1):44–53.8234918
Steadman B, Farag A, Bergman H. 1991. Exposure-related patterns of biochemical indicators in rainbow trout exposed to no. 2 fuel oil. Environ Toxicol Chem 10(3):365–374.
*Steele RW, Conklin RH, Mark HM. 1972. Corticosteroids and antibiotics for the treatment of fulminant hydrocarbon aspiration. JAMA 219( 11): 1434–1437.5066898
Stenzel H, Rodicker H. 1991. Results of substance groups and structural groups analysis of petroleum fractions and their application in estimating the correlation for predicting properties. Chemische Technik 43:344–346.
Stewart PA, Lee JS, Marano DE, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility: II. Exposures and their assessment. Br J Int Med 48(8):531–537.
*STORET. 1992. Storage and Retrieval Database. Washington, DC: U.S. Environmental Protection Agency, Office of Water.
*Strand J, Cullinan V, Crecelius E, 1992. Fate of bunker-c fuel in Washington costal habitats following the december 1988 Nestucca oil spill. Northwest Science 66:1–14.
*Strayer RF, Edwards NT, Walton BT, 1983. Potential terrestrial fate and effects on soil biota of a coal liquification product spill. Environmental Toxicology and Chemistry 2(2):217–224.
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 360–361.
*Subcommittee on Accidental Poisoning. 1962. Co-operative kerosene poisoning study: Evaluation of gastric lavage and other factors in the treatment of accidental ingestion of petroleum distillate products. Pediatrics 648–674.
Sun X. 1991. Heating fuels and respiratory diseases in the risks of female lung cancer. Chin J Oncol 13(6):413–415.
Swader N. 1975. Persistence & effects of light fuel oil in soil. 1975 Conference on Prevention and Control of Oil Pollution San Francisco, California.
*Tagami H, Ogino A. 1973. Kerosine dermatitis: Factors affecting skin irritability to kerosine. Dermatologica 146(2):123–131.4711878
*Tal A, Aviram M, Bar-Ziv J, 1984. Residual small airways lesions after kerosene pneumonitis in early childhood. Eur J Pediatr 142(4): 117–120.6468426
Tandon J, Kalra A, Sahu S, 1993. Profile of accidents in children. Indian Pediatr 30(6):765–769.8132256
*Teal J, Farrington J, Burns K, 1992. The West Falmouth oil spill after 20 years fate of fuel oil compounds and effects on animals. Mar Pollut Bull 24(12):607–614.
*Teal JM, Burns K, Farrington JW. 1978. Analyses of aromatic hydrocarbons in intertidal sediments resulting from two spills of no. 2 fuel oil in Buzzards Bay, Massachusetts. Journal of Fisheries Research Board - Canada 35(5):510–520.
Temple WA, Ferry DG. 1988. Solvent exposures and risk assessment. In: Richardson ML, ed. Risk assessment of chemicals in the environment: Third European Conference, Guilford, England, UK, July 11-14, 1988. London, England: Royal Society of Chemistry, 222–241.
*Theobald N. 1988. Rapid preliminary separation of petroleum hydrocarbons by solid-phase extraction cartridges. Anal Chim Acta 204(1-2):135–144.
Thilly WG, Longwell J, Andon BM. 1983. General approach to the biological analysis of complex mixtures. Environ Health Perspect 48:129– 136.6337832
*Thomas DH, Delfino JJ. 1991a. A gas-chromatographic/chemical indicator approach to assessing ground water contamination by petroleum products. Ground Water Monitoring Review 11(4):90–100.
Thomas DH, Delfino JJ. 1991b. Analytical methods and chemical indicators for assessing groundwater contamination by petroleum products [Abstract]. Abs Pap Am Chem Sot 201(1):Envr 40.
Thurston GD, Spengler JD. 1985. A quantitative assessment of source contributions to inhalable particulate matter pollution in metropolitan Boston. Atmos Environ 19(1):9–25.
Tichenor BA, Sparks LA, White JB, 1990. Evaluating sources of indoor air pollution. J Air Waste Manage Assoc 40(4):487–492.2340148
Todaro A, Bronsato R, Buratti M, 1991. Acute exposure to vanadium-containing dusts: the health effects and biological monitoring in a group of workers employed in boiler maintenance. Med Lav 82(2):142–147.1770872
Tokiwa H, Nakagawa R, Horikawa K. 1985. Mutagenic/carcinogenic agents in indoor pollutants: The dinitropyrenes, generated by kerosene heaters and fuel gas and liquefied petroleum gas burners. Mutat Res 157(1):39–47.3892284
Tokiwa H, Nakagawa R, Horikawa K, 1987. The nature of the mutagenicity and carcinogenicity of nitrated, aromatic compounds in the environment. Environ Health Perspect 73: 191–199.3117527
*Tominaga S, Itoh K. 1985. Relationship between parental smoking and respiratory diseases of three year old children. Tokai J Exp Clin Med 10(4):395–399.3836522
*Toriyama S, Shimada H, Arakawa H, 1991. An estimate of source contribution of atmospheric aerosols in Toyama Prefecture by chemical mass balance method. Nippon Kagaku Kaishi N 5:454–464.
*TRI90. 1992. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Truffa O, Montalenti P. 1969. [Acute pneumopathy and jaundice caused by accidental ingestion of kerosene.] Minerva Med 60(30):1403–1406. (Italian)5783312
*Tu K, Knutson E, George A. 1991. Indoor Radon Progeny aerosol size measurements in urban, suburban, and rural regions. Aerosol Science and Technology 15:170–178.
Tucker WG. 1987. Characterization of emissions from combustion sources: Controlled studies. Atmos Environ 21(2):281–284.
*Upreti RK, Das M, Shanker R. 1989. Dermal exposure to kerosene. Vet Hum Toxicol 31(1):16–20.2523616
Uri N, Day K. 1992. The Dieselization of American Agriculture. International Journal of Energy Research 16:129–137.
Urmey W, Scharf S, Song P, 1980. Effects of interstitial fluid on lung mechanics in the rat. Federation of American Societies for Experimental Biology 64th Annual Meeting Anahiem, California.
Vernon A, Church T, Patterson C, 1992. Continental origin and industrial sources of trace-metals in the northwest atlantic troposphere. Journal of Atmospheric Chemistry 14:339–351.
Vernot EH, Drew RT, Kane ML. 1990a. Acute toxicological evaluation of hydrosulfurized kerosine. Acute Toxic Data 1(1):31–32.
Vernot EH, Drew RT, Kane ML. 1990b. Acute toxicological evaluation of jet fuel A. J Am Co11 Toxicol Part B 1(2):29–30.
Vernot EH, Drew RT, Kane ML. 1990c. Acute toxicologic evaluation of #6 fuel oil. Acute Toxic Data 1(2):137.
*Vernot EH, Drew RT, Kane ML. 1990d. Acute toxicological evaluation of straight run kerosene. J Am Co11 Toxicol Part B 1(1):30–31.
Viegi G, Paoletti P, Carrozzi L, 1989a. Adverse health effects of exposure to indoor pollutants in young non-smokers from a general population sample of North Italy. Am Rev Respir Dis 13(4 part 2):A563.
Viegi G, Paoletti P, Carrozzi L, 1989b. Effects of indoor pollutants on respiratory symptoms and lung function of a general population sample in North Italy. In: Proceedings of the Air and Waste Management Association 82nd Annual Meeting and Exhibition, Anaheim, CA, June 25-30, 1989. Pittsburgh, PA: Air and Waste Management Association, l-l 1.
*Wade TL, Quinn JG. 1980. Incorporation, distribution, and fate of saturated petroleum hydrocarbons in sediments from a controlled marine ecosystem. Marine Environmental Research 3(1):15–34.
*Walker JD, Colwell RR. 1975. Some effects of petroleum on estuarine and marine microorganisms. Can J Microbial 21(3):305–313.
*Walker JD, Petrakis L, Colwell RR. 1976. Comparison of the biodegradability of crude and fuel oils. Can J Microbial 22(4):598–602.
Wallace L. 1992. Recent field studies of personal and indoor exposures to environmental pollutants. Ann New York Acad Sci 641:7–16.1580482
Walton B, Buchanan M. 1980. Teratogenic effects of fuel oils on insects developing in contaminated substrates. Second Chemical Congress of the North American Continent San Francisco, California.
*Waring JI. 1933. Pneumonia in kerosene poisoning. Am J Med Sci 185:325–330.
Watts R, McGuire P. 1992. Emergency Services to Conduct Laboratory Research Concerning Appropriate Additions at NAS Patuxent River Fuel Farm In situ Bioreclamation. Nevada Univ, Reno Dept of Civil Engineering Reno Nevada.
*Westerholm R, Egebaeck K. 1991. Impact of fuels on diesel exhaust emissions. A chemical and biological characterization. National Environmental Protection Agency Solna, Sweden.
*WHO. 1991. Indoor air quality: Combustion products. Environmental Technology 12:829–831.
Wickramanayake G, Arther M, Pollack A, 1992. Removal of Aqueous Phase Petroleum Products in Groundwater by Aeration. Battelle Columbus Labs OH.
Weil CS, Condra NI. 1977. Experimental carcinogenesis of pyrolysis fuel oil. Am Ind Hyg Assoc J 38(12):730–733.930825
*Williams UP, Kiceniuk JW, Fancey LL, 1989. Tainting and depuration of taint by lobsters (Homarus americanus) exposed to water contaminated with a no. 2 fuel oil: Relationship with aromatic hydrocarbon content in tissue. J Food Sci 54(2):240–243.
*Williams U, Kiceniuk J, Fancey L, 1991. Tainting and Depuration of Taint by Lobsters Homarus-Americanus exposed to water contaminated with a no. 2 fuel oil relationship with aromatic hydrocarbon content in tissue. J Food Sci 54(2):240–243.
*Wilson AL, Harrer RD, Holtz DR. 1978. Hydrocarbon emissions from fixed-roof storage tanks. Proceeding of the 71st Annual Meeting of the Air Pollution Control Association 1:78–8.3.
*Witschi HP, Smith LH, Frome EL. 1987. Skin tumorigenic potential of crude and refined coal liquids and analogous petroleum products. Fundamental and Applied Toxicology. 9:297–303.3653572
*Wolfe BM, Brodeur AE, Shields JB. 1970. The role of gastrointestinal absorption of kerosene in producing pneumonitis in dogs. J Pediatr 76(6):867–873.5444579
Wolff GT, Korsog PE. 1985. Estimates of the contributions of sources to inhalable particulate concentrations in Detroit. Atmos Environ 19(9): 1399–1409.
Wolfsdorf J. 1976. Experimental kerosene pneumonitis in primates: Relevance to the therapeutic management of childhood poisoning. Clin Exp Pharmacol Physiol 3(6):539–544.827406
*Wolfsdorf J, Kundig H. 1972. Kerosene poisoning in primates. S Afr Med J 46(20):619–621.4625017
*Wolfsdorf J, Kundig H. 1974. Dexamethasone in the management of kerosene pneumonia. Pediatrics 53(1):86–90.4203313
Wolfsdorf J, Paed D. 1976. Kerosene intoxication: An experimental approach to the etiology of the CNS manifestations in primates. J Pediatr 88(6):1037–1040.818358
Woodring JL, Duffy TL, Davis JT, 1985. Measurements of combustion product emission factors of unvented kerosene heaters. An Ind Hyg Assoc J 46(7):350–356.
Worfley P, Vaughan T, Davis S, 1992. A case-control study of occupational risk factors for laryngeal cancer. British Journal of Industrial Medicine 49(12): 837–844.1472441
*Yamaguchi S, Yamamoto H, Mizukoshi R, 1992. Rapid chemical diagnosis of kerosene ingestion by NMR. Clinical Chemistry. 38(4):593.
Yamanaka S, Maruoka S. 1984. Mutagenicity of the extract recovered from airborne particles outside and inside a home with an unvented kerosine heater. Atmos Environ 18(7):1485–1487.
Yamanaka S, Hirose H, Takada S. 1979. Nitrogen oxides emissions from domestic kerosene-fired and gas-fired appliances. Atmos Environ 13(3):407–412.435330
*Yaron B, Sutherland P, Galin T, 1989. Soil pollution by petroleum products: II. Adsorption-desorption of “kerosene” vapors on soils. Journal of Contaminant Hydrology 4:347–358.
Yokoyana Y, Bitta H, Maeda K, 1985. What interaction does indoor nitrogen dioxide have on the effect of the automobile exhaust. Tokai J Exp Clin Ned 10(4):379–384.
Zeiger E, Anderson B, Haworth S, 1987. Salmonella mutagenicity tests: 3. Results from the testing of 255 chemicals. Environ Mutagen 9 (Suppl 9):1–110.
*Zheng J, Quinn JG. 1988. Petroleum hydrocarbon contamination of ground water in Tiverton, Rhode Island, USA. Chin J Oceanol Limnol 6(4):367–375.
*Zheng W, Blot WJ, Shu X, 1992. Risk factors for oral and pharyngeal cancer in Shanghai, with emphasis on diet. Cancer Epidemiol Biomarkers Prev 1:441–448.1302555
*Zieserl E. 1979. Hydrocarbon ingestion and poisoning. Compr Ther 5(6):35–42.
*Zucker AR, Berger S, Wood LD. 1986. Management of kerosene-induced pulmonary injury. Crit Care Med 14(4):303–304.3082595
Zucker AR, Berger S, Becker CJ, 1987. Effects of PEEP on kerosene induced pulmonary edema. Am Rev Respir Dis 135(4 Part 2):A428.
Zucker AR, Wood LD H, Curet-Scott M, 1991. Partial lung bypass reduces pulmonary edema induced by kerosene aspiration in dogs. J Crit Care 6(1):29–35).