# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding fuel oils in air, water, and other media are summarized in Table 7-1. There are only a few regulations that are specific to a particular fuel oil and these are indicated in the table.

An acute inhalation MRL of 0.02 mg/m^3^ was derived for fuel oil no. 2. The MRL is based on a LOAEL value of 65 mg/m^3^ for neurobehavioral effects (mild transient ataxia and CNS depression) in mice exposed to airborne concentrations of fuel oil no. 2.

An intermediate inhalation MRL of 0.01 mg/m^3^ was derived for fuel oil no. 1. The MRL is based on decreased blood glucose levels in male rats exposed to airborne concentrations of kerosene averaging 58 mg/m3 for 6 hours/day, 6 days/week for 14 weeks. Rats exposed to airborne concentrations of kerosene averaging 231 mg/m^3^ showed a decrease in blood glucose titers, as well as increased circulating levels of lactate and pyruvate.

The EPA has no oral reference dose (RfD) or inhalation reference concentration (RfC) for any of the fuel oils.

Under the Hazardous Materials Transportation Act, fuel oils are designated as hazardous substances subject to special requirements for packaging, labeling, and transportation (DOT 1989a, 1989b).

TABLE 7-1 Regulations and Guidelines Applicable to Fuel Oils

Agency | Description | Information | References
[underlined: INTERNATIONAL]
IARC | Carcinogenic classification | | IARC 1989
| for occupational exposures in petroleum refining | Group 2A^a^
| Carcinogenic classification
| marine diesel fuel | Group 2B^b^
| residual (heavy) fuel oils | Group 2B
| jet fuels | Group 3^c^
| distillate (light) diesel fuels | Group 3
[underlined: NATIONAL]
Regulations:
a. Air:
AFOSH | PEL TWA | | Air Force 1989
| Petroleum distillates (naphtha) | 400 ppm
| STEL (15 minutes)
| Petroleum distillates (naphtha) | 500 ppm
NIOSH | TWA
| Petroleum distillates (naphtha) | 85 ppm (350 mg/m^3^) | NIOSH 1992
| Ceiling REL (15 minutes)
| Petroleum distillates (naphtha) | 438 ppm (1,800 mg/m^3^)
| IDLH
| Petroleum distillates (naphtha) | 10,000 ppm | NIOSH 1990
OSHA | PEL TWA | | OSHA 1989a (29 CFR 1910.1000); OSHA 1989b
| Petroleum distillates (naphtha) | 400 ppm | OSHA 1989a (29 CFR 1910.1000); OSHA 1989b
b. Other:
DOT | Hazardous Material Transportation Act: Fuel oils are designated as hazardous materials which are subject to requirements for packaging, shipping, and transporting | Yes | DOT 1989a (49 CFR 172.101 Appendix A); DOT 1989b
EPA | Toxic Substances Control Act: Manufacturers and processors of the C_9_ aromatic hydrocarbon fraction must test this fraction for the following: neurotoxicity, mutagenicity, developmental toxicity, reproductive effects, and oncogenicity | Yes | EPA 1991a (40 CFR 799.2175); EPA 1987c
EPA | Marine Protection Research and Sanctuaries Act: Ocean dumping of organohalogen compounds or oils of any kind which are known or suspected carcinogens, mutagens, or teratogens is prohibited except when they are present as trace contaminants | Yes | EPA 1991b (40 CFR 227.6)
Guidelines:
a. Other:
EPA | Domestic water supply must be virtually free from oil and grease, particularly from the tastes and odors that emanate from petroleum products | Yes | EPA 1986c
| For aquatic life, levels must be ≤ 0.01 of the lowest continuous flow 96-h LC_50_ | Yes | EPA 1986c
| Clean Water Act: Oil and grease are designated as conventional pollutants. Effluent limitations for oil and grease (polynuclear aromatic hydrocarbons) exist for almost all point sources under the general pretreatment standards for new and existing sources | Yes | EPA 1988b (40 CFR 403.2); EPA 1988c
| Pesticide subject to registration and/or reregistration (kerosene) | Yes | EPA 1989c (40 CFR 152.146); EPA 1989b
[underlined: STATE]
Regulations and Guidelines:
a. Air:
| Acceptable ambient air concentrations (Navy Fuels JP-5) | | NATICH 1991
Connecticut | (8 hour) | 2.00×10^3^ μg/m^3^
Maryland | | 0.00
Oklahoma | (24 hour) | 1.00×10^4^ μg/m^3^
Texas | (30 minutes) | 1.00×10^3^ μg/m^3^
Texas | (annual) | 1.00×10^2^ μg/m^3^
| Regulations on hydrocarbon emissions (kerosene, petroleum distillates, diesel, fuel oil) | Yes | CELDS 1991
Connecticut
Kansas
Wisconsin
| Regulations on volatile organic carbon emissions (VOC) | Yes | CELDS 1991
Alabama
Arizona
Florida
Maine
Maryland
Michigan
New Jersey
South Carolina
Virginia
Texas
Washington, DC
Maine | Regulations on the open burning of fuel oils (kerosene) | Yes | CELDS 1991
Texas | Regulations for gas processing plants | Yes | CELDS 1991
b. Water:
Alaska | Aquatic life criterion for total hydrocarbons in marine and surface waters | 15 μg/L | State of Alaska 1989
| Aquatic life criterion for aromatic hydrocarbons in marine and surface waters | 10 μg/L | State of Alaska 1989
Arkansas | Average or maximum allowable quantity of oil or grease discharged into surface waters | 10 mg/L (average); 15 mg/L (maximum) | State of Arkansas 1991
Florida | Average or maximum allowable quantity of oil or grease discharged Class V waters (navigation, industrial use) | 10 mg/L | State of Rorida 1992
| Average or maximum allowable quantity of oil or grease discharged into all other surface waters | 5 mg/L | State of Florida 1992
Maine | Drinking water quality guidelines and standards (fuel oil no. 2) | 100 μg/L | FSTRAC 1988
Massachusetts | Maximum discharge concentration of oil or grease of petroleum origin in surface waters | 15 mg/L | Commonwealth of Massachusetts 1988
Nebraska | Maximum petroleum oil concentration in surface waters | 10 mg/L | State of Nebraska 1991
New York | Maximum contaminant level of kerosone in drinking water | 50 μg/mL | State of New York 1989
South Dakota | Water quality standard for all petroleum products in surface waters | 10 mg/L | State of South Dakota 1989
Virginia | Water quality standard for petroleum hydrocarbons in ground water | 1 mg/L | Commonwealth of Virginia 1988
Wyoming | Water quality standard for all surface waters classes | 10 mg/L | State of Wyoming 1990
c. Other:
| Regulations on the transport of flammable/hazardous liquids (petroleum distillates or VOC) | Yes | CELDS 1991
Colorado
Maryland
Massachusetts
Wisconsin
Maine | Regulations on the disposal of special wastes including diesel fuels | Yes | CELDS 1991
California | Regulations on leaking underground fuel tanks | Yes | CELDS 1991
Wyoming | Regulations on well drilling for oil | Yes | CELDS 1991
Rhode Island | Regulations on oil pollution | Yes | CELDS 1991

a Group 2A = Probably carcinogenic to humans. This classification is not specified for the fuel oils discussed in this profile, nor for exposure to fuel oils by the general population; rather, this classification applies only to occupational exposures in petroleum refining.

b Group 2B = Possibly carcinogenic to humans

c Group 3 = Not classifiable as to its carcinogenicity to humans

AFOSH = Air Force Office of Health and Safety; CELDS = Computer-Environmental Legislative Data System; DOT = Department of Transportation; EPA = Environmental Protection Agency; IARC = International Agency for Research on Cancer; IDLH = Immediately Dangerous to Life or Health; NATICH = National Air Toxics Information Clearinghouse; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PEL = Permissible Exposure Limit; REL = Recommended Exposure Limit; STEL = Short Term Exposure Limit; TWA = Time-Weighted Average; VOC = Volatile Organic Compounds