# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of fuel oils is located in Table 3-1. Information on the composition of selected fuel oils, specifically fuel oil no. 2 and kerosene, is presented in Table 3-2.

All of the fuel oil classes discussed in this Profile are refined from crude petroleum and may be categorized as either a distillate fuel or a residual fuel depending on the method of production. Fuel oils no. 1 and no. 2 are distillate fuels which consist of distilled process streams. Residual fuel oils such as fuel oil no. 4 are residues remaining after distillation or cracking, or blends of such residues with distillates (IARC 1989). Diesel fuels are approximately similar to fuel oils used for heating (fuel oils no. 1, no. 2, and no. 4). All fuel oils consist of complex mixtures of aliphatic and aromatic hydrocarbons. The aliphatic alkanes (paraffins) and cycloalkanes (naphthenes) are hydrogen saturated and compose approximately 80-90% of the fuel oils. Aromatics (e.g., benzene) and olefins (e.g., styrene and indene) compose 10-20% and l%, respectively, of the fuel oils. Fuel oil no. 1 (straightrun kerosene) is a light distillate which consists primarily of hydrocarbons in the C_9_—C_16_ range; fuel oil no. 2 is a heavier, usually blended, distillate with hydrocarbons in the C_11_-C_20_ range. Straight-run distillates may also be used to produce fuel oil no. 1 and diesel fuel oil no. 1. Diesel fuel no. 1 and no. 2 are similar in chemical composition to fuel oil no. 1 and fuel oil no. 2, respectively, with the exception of the additives. Diesel fuels predominantly contain a mixture of C_10_ through C_19_ hydrocarbons, which include approximately 64% aliphatic hydrocarbons, l-2% olefinic hydrocarbons, and 35% aromatic hydrocarbons (Air Force 1989). Jet fuels are based primarily on straight-run kerosene, as well as additives. All of the above fuel oils contain less than 5% polycyclic aromatic hydrocarbons. Fuel no. 4 (marine diesel fuel) is less volatile than diesel fuel no. 2 and may contain up to 15% residual process streams, in addition to more than 5% polycyclic aromatic hydrocarbons (IARC 1989). Residual fuel oils are generally more complex in composition and impurities than distillate fuel oils; therefore, a specific composition cannot be determined (Air Force 1989). Sulfur content in residual fuel oils has been reported to be from 0.18% to 4.36% by weight.

TABLE 3-1 Chemical Identity of Fuel Oils

Characteristic | Fuel oil no. 1 | Fuel oil no. 1-D | Fuel oil no. 2 | Fuel oil no. 2-D | Fuel oil no. 4 | Fuel oil UNSP
Synonym(s) | Kerosene; coal oil; kerosine; range oil; straight run kerosene; distillate fuel oils, light; furnace oil no. 1 ; Deobase^®^; JP-5; JP-1; range oil^a,b,c^ | Diesel fuel; diesel fuel oil no. 1; diesel oil no. 1; no. 1 diesel; diesel oil (light); Arctic diesel^a,d,e^ | API no. 2 fuel oil; gas oil; home heating oil no. 2; number 2 burner oil; diesel fuel; furnace oil no. 2^b^ | Diesel fuel; diesel fuel oil no. 2; diesel oil no. 2; no. 2 diesel; diesel oil (medium)^a,d,e^ | Oil, fuel, no. 4; residual fuel oil no. 4; no. 4 fuel oil; residual fuel oil; marine boiler fuel; marine diesel fuel; diesel fuel no. 4; grade 4^a,d,e^ | No data
Registered trade name(s) | Deobase^®^ ^c^ | No data | No data | No data | No data | No data
Chemical formula^f^ | No data | No data | No data | No data | No data | No data
Chemical structure^f^ | No data | No data | No data | No data | No data | No data
Identification numbers:
CAS registry | 8008-20-6770892-10-3^e^ | No data | 68476-30-2^d^ | 68476-34-6^a^ | 68476-31-3^b^ | No data
NIOSH RTECS | OA5500000^c^ | No data | HZ1800000^d^ | No data | No data | LS8950000^d^
EPA hazardous waste | No data | No data | No data | No data | No data | No data
OHM/TADS | 7217063^e^ | No data | No data | No data | 7217065^e^ | No data
DOT/UN/NA/IMCO shipping | UN 1223; IMO 3.3^e^ | No data | No data | No data | No data | No data
HSDB | 632^c^ | No data | No data | No data | No data | No data
NCI | No data | No data | C54795^g^ | No data | No data | No data

a IARC 1989

b RTECS 1991

c HSDB 1991

d Air Force 1989

e OHM/TADS 1985

f Fuel oils are mixtures of various hydrocarbons designed to meet specifications set forth by the American Society for Testing and Materials (IARC 1989); therefore, chemical structure, chemical formula, and molecular weight cannot be determined.

g Sax and Lewis 1989

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/Intemational Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

TABLE 3-2 Analysis of Fuel Oils^a^

| Volume %
Hydrocarbon type | Fuel oil no. 1 | Fuel oil no. 2
Paraffins (n- and iso-) | 52.4 | 41.3
Monocycloparaffins | 21.3 | 22.1
Bicycloparaffins | 5.1 | 9.6
Tricycloparaffins | 0.8 | 2.3
Total saturated hydrocarbons | 79.7 | 75.3
Olefins | No data | No data
Alkylbenzenes | 13.5 | 5.9
Indans/tetralins | 3.3 | 4.1
Dinaphthenobenzenes/indenes | 0.9 | 1.8
Naphthalenes | 2.8 | 8.2
Biphenyls/acenaphthenes | 0.4 | 2.6
Fluorenes/acenaphthylenes | No data | 1.4
Phenanthrenes | No data | 0.7
Total aromatic hydrocarbons | 23.6 | 24.7

a Derived from IARC 1989; provided by the American Petroleum Institute

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of fuel oils is located in Table 3-3.

TABLE 3-3 Physical and Chemical Properties of Fuel Oils^a^

Characteristic | Fuel oil no. 1 | Fuel oil no. 1-D | Fuel oil no. 2 | Fuel oil no. 2-D | Fuel oil no. 4 | Fuel oil no. UNSP
Molecular weight | No data | No data | No data | No data | No data | No data
Color | Pale yellow^b^; Colorless to brown^c,d^ | Colorless to brown^c^ | Colorless to brown^c^ | Colorless to brown^c^ | Colorless to brown^c^ | Colorless to brown^c^
Physical state | Liquid^c^ | Liquid^c^ | Liquid^c^ | Liquid^c^ | Liquid^c^ | Liquid^c^
Melting point | −45.6°C^d^ | −34°C^d^ | −29°C^d^ | 18°C^d^ | −29°C to −9°C^d^; −46°C^e^ | −48°C-18°C^c^
Boiling point | 175–325°C^b^; 200–260°C^d^ | 193–293°C^d^ | 160–360°C^f^ 282–338°C^d^ | 282–338°C^d^ | 101–588°C^d^ | 151->588°C^c^
Density:
At 15°C | 0.810–0.9360 g/mL^c^ | 0.810–0.9360 g/mL^c^ | No data | No data | 0.810–0.9360 g/mL^c^ | No data
At 20°C | 0.80 g/mL^e,f^ | No data | 0.8700–0.9500^c^ | 0.8700–0.9500 g/mL^c^ | 1 g/mL^e^ | No data
Odor | Kerosene-like^c^ | Kerosene-like^c^ | Kerosene-like^c^ | Kerosene-like^c^ | Kerosene-like^c^ | Kerosene-like^c^
Odor threshold (ppm) | 0.082^f^; 1^d^ | 0.7^d^ | No data | No data | 0.5^e^ | No data
Solubility
Water at 20°C | ≈5 mg/L^c^ | ≈5 mg/L^c^ | ≈5 mg/L^c^ | ≈5 mg/L^c^ | ≈5 mg/L^c^ | ≈5 mg/L^c^
Organic solvent(s) | Miscible with other petroleum solvents^b^ | No data | No data | No data | No data | No data
Partition coefficients:
Log K_ow_ | 3.3–7.06^c^ | 3.3–7.06^c^ | 3.3–7.06^c^ | 3.3–7.06^c^ | 3.3–7.06^c^ | 3.3–7.06^c^
Log K_oc_ | 3.0–6.7^c^ | 3.0–6.7^c^ | 3.0–5.7^c^ | 3.0–6.7^c^ | 3.0–6.7^c^ | 3.0–6.7^c^
Vapor pressure at 21°C | 2.12–26.4 mmHg^c^ | 2.12–26.4 mmHg^c^ | 2.12–26.4 mmHg^c^ | 2.12–26.4 mmHg^c^ | 2.12–26.4 mmHg^c^ | 2.12–26.4 mmHg^c^
Henry’s law constant
at 20°C - atm-m^3^/mol | 5.9 × 10^−5^–7.4^c^ | 5.9 × 10^−5^–7.4^c^ | 5.9 × 10^−5^–7.4^c^ | 5.9 × 10^−5^–7.4^c^ | 5.9 × 10^−5^–7.4^c^ | 5.9 × 10^−5^–7.4^c^
Autoignition temperature | 229°C^d^ | 177.0–329.0°C^d^ | 257°C^d^ | 254–285°C^d^ | 263°C^d^ | No data
Flashpoint (close cup) | 38°C^c,d^ | 38°C^d,f^ | 58°C^d^ | 52°C^d,f^ | 55°C^f^;>54°C^d^ | No data
Flammability limits
(% volume in air) | 0.7%-5%^d^ | 1.3–6.0%^d^ | 0.6–7.5%^d^ | 1.3–6.0%^d^ | 1.0–5.0%^d^ | [c]No data
Conversion factors | No data | No data | No data | No data | No data | No data
Explosive limits | 0.7%-5%^b^ | No data | No data | No data | No data | No data

a Values listed are specifications required or general characteristics of each class of fuel oils.

b HSDB 1991

c Air Force 1989

e OHM/TADs 1985

d Coast Guard 1985

f IARC 1989