# 8 REFERENCES

* Cited in text

3M Company. 1985. Organic vapor method no. 4D. 3M Company Occupational Health and Safety Products Laboratory. May 1985.
*Aaron CK, Howland MA. 1994. Goldfrank's Toxicological emergencies. Norwalk, CT: Appleton and Lange.
Abbott FV, Franklin KB, Libman RB. 1986. A dose-ratio comparison of Mu and Kappa agonists in formalin and thermal pain. Life Sci 39:2017–2024.3023775
Abbott FV, Hong Y, Blier P. 1997. Persisting sensitization of the behavioural response to formalin-induced injury in the rat through activation of serotonin_2A_ receptors. Neuroscience 77:575–584.9472413
*ACGIH. 1992. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
ACGIH. 1995. 1995–1996 Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1998. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Acheson ED, Barnes HR, Gardner MJ, 1984a. Formaldehyde process workers and lung cancer. Lancet 1:1066–1067.
Acheson ED, Gardner MJ, Pannett B, 1984b. Formaldehyde in the British chemical industry. Lancet 1:611–616.6142316
*Adams DO, Hamilton TA, Lauer LD, 1987. The effect of formaldehyde exposure upon the mononuclear phagocyte system of mice. Toxicol Appl Pharmacol 88:165–174.3564036
Adams RM, Maibach HI. 1985. A five-year study of cosmetic reactions. J Am Acad Dermatol 13:1062–1069.4078100
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Addy M, Mostafa P. 1988. Dentine hypersensitivity. I. Effects produced by the uptake in vitro of metal ions, fluoride and formaldehyde onto dentine. J Oral Rehab 15:575–585.
*Akbar-Khanzadeh F, Mlynek JS. 1997. Changes in respiratory function after one and three hours of exposure to formaldehyde in non-smoking subjects. Occup Environ Med 24:296–300.
*Akbar-Khanzadeh F, Vaquerano MU, Akbar-Khanzadeh M, 1994. Formaldehyde exposure, acute pulmonary response, and exposure control options in a gross anatomy laboratory. Am J Ind Med 26:61–75.8074125
Akubue PI, Stohs SJ. 1993. Effect of alachlor on the urinary excretion of malondialdehyde, formaldehyde, acetaldehyde, and acetone by rats. Bull Environ Contam Toxicol 50:565–571.8467143
Akubue PI, Bagchi D, Ihm WJ, 1994. Excretion of malondialdehyde, formaldehyde, acetaldehyde, acetone and methyl ethyl ketone in the urine of rats given an acute dose of malondialdehyde. Arch Toxicol 68:338–341.8085947
*Albert RE, Sellakumar AR, Laskin S, 1982. Gaseous formaldehyde and hydrogen chloride induction of nasal cancer in the rat. J Natl Cancer Inst 68:597–603.6951075
Alderson T. 1985. Formaldehyde-induced mutagenesis: a novel mechanism for its action. Mutat Res 154:101–110.3929079
*Alexandersson R, Hedenstierna G. 1988. Respiratory hazards associated with exposure to formaldehyde and solvents in acid-curing paints. Arch Environ Health 43:222–227.3260092
*Alexandersson R, Hedenstierna G. 1989. Pulmonary function in wood workers exposed to formaldehyde: A prospective study. Arch Environ Health 44:5–11.2916856
Alfheim JA, Langford CH. 1985. Determination of formaldehyde with the thermal lens effect. Anal Chem 57:861–864.
Alldredge AL, Elias M, Gotschalk CC. 1986. Effects of drilling muds and mud additives on the primary production of natural assemblages of marine phytoplankton. Mar Environ Res 19:157–176.
Aloisi AM, Zimmermann M, Herdegen T. 1997. Sex-dependent effects of formalin and restraint on C-Fos expression in the septum and hippocampus of the rat. Neuroscience 81:951–958.9330358
*Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III, 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Altshuller AP. 1993. Production of aldehydes as primary emissions and from secondary atmospheric reactions of alkenes and alkanes during the night and early morning hours. Atmos Environ 27:21–32.
*Amdur MO. 1960. The response of guinea pigs to inhalation of formaldehyde and formic acid alone and with a sodium chloride aerosol. Int J Air Pollut 3:201–220.13682962
Ancona-Alayon A, Jimenez-Castilla JL, Gomez-Alvarez EM. 1976. Dermatitis from epoxy resin and formaldehyde in shampoo packers. Contact Dermatitis 2:356–364.
Andersen I. 1986. Effects of airborne substances on nasal function in human volunteers. In: Barrow CS, ed. Toxicology of the nasal passages. Washington, DC: Hemisphere Publishing Corporation, 143–154.
*Andersen I, Molhave L. 1983. Controlled human studies with formaldehyde. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 154–165.
*Andersen ME, Kirshnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ 3rd, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Andjelkovich AA, Mathew RM, Richardson RB, 1990. Mortality of iron foundry workers: I. Overall findings. J Occup Med 32:529–540.2166148
Andjelkovich DA, Levine RJ. 1988. Identification of an industrial cohort and verification of its completeness using a complicated system of plant records. Am J Ind Med 13:593–599.3376948
*Andjelkovich DA, Janszen DB, Brown MH, 1995a. Mortality of iron foundry workers: IV. Analysis of a subcohort exposed to formaldehyde. J Occup Environ Med 37:826–837.7552467
Andjelkovich DA, Janszen DB, Conolly RB, 1995b. Formaldehyde exposure not associated with cancer of the respiratory tract in iron foundry workers: A synopsis of CIIT epidemiologic findings. CIIT Act 15:1–9.
Andjelkovich DA, Mathew RM, Levine RJ. 1994a. Letters to the Editor. J Occup Med 36:468.8014721
Andjelkovich DA, Mathew RM, Yu RC, 1992. Mortality of iron foundry workers. II. Analysis by work area. J Occup Med 34:391–401.1564577
*Andjelkovich DA, Shy CM, Brown MH, 1994b. Mortality of iron foundry workers. III. Lung cancer case-control study. J Occup Med 36:1301–1308.7884571
Ang CC, Lipari F, Swarin SJ. 1987. Determination of hydroxymethanesulfonate in wet deposition samples. Environ Sci Technol 21:102–105.
Anonymous. 1982. Report of the federal panel of formaldehyde. Environ Health Perspect 43:139–168.6977445
*Anonymous. 1984a. Report on the consensus workshop on formaldehyde. Environ Health Perspect 58:323–381.6525992
Anonymous. 1984b. Final report on the safety assessment of formaldehyde. J Am Coll Toxicol 3:157–184.
Anonymous. 1984c. No title available. Chem Eng News 62: 13, 17–20.
*Anonymous. 1992. Production by the U.S. Chemical Industry: Chemical production held steady in 1991. Chem Eng News 70:34–40.
*Anonymous. 1993. Formaldehyde [Abstract]. Chem Ind News November-December 1993:8.
*Anonymous. 1994. Production by the U.S. Chemical Industry: Growth continues in chemical production. Chem Eng News 72:30–36.
*Anonymous. 1995a. Production by the U.S. Chemical Industry: Production soared in most chemical sectors. Chem Eng News 73:36–42.
*Anonymous. 1995b. Formaldehyde. Chem Mark Rep September 11, 1995:39–41.
*Anonymous. 1998. Formaldehyde. Chem Mark Rep June 22, 1998:49.
Apfelbach R, Reibenspies M. 1991. Olfactory learning is inhibited after low-level formaldehyde gas exposure in the ferret [Abstract]. Chem Senses 16:498.
Apfelbach R, Weiler E. 1991. Sensitivity to odors in Wistar rats is reduced after low-level formaldehyde-gas exposure. Naturwissenschaften 78:221–223.1852218
Apfelbach R, Reibenspies M, Schmidt R. 1992. The effect of long-lasting formaldehyde gas exposure on the olfactory epithelium and on the olfactory discrimination ability in the ferret [Abstract]. Chem Senses 17:590–591.
*Appelman LM, Woutersen RA, Zwart A, 1988. One-year inhalation toxicity study of formaldehyde in male rats with a damaged or undamaged nasal mucosa. J Appl Toxicol 8:85–90.3379235
*Arnts RR, Tejada SB. 1989. 2,4-Dinitrophenylhydrazine-coated silica gel cartridge method for determination of formaldehyde in air: Identification of an ozone interference. Environ Sci Technol 23:1428–1430.
Arts JH E, Dröge SC M, Spanhaak S, 1997. Local lymph node activation and IgE responses in brown Norway and Wistar rats after dermal application of sensitizing and non-sensitizing chemicals. Toxicology 117:229–237.9057902
Ashby J, Lefevre P. 1983. Genetic toxicology studies with formaldehyde and closely related chemicals including hexamethylphosphoramide (HMPA). In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 85–97.
Ashby J, Callander RC, Rose FL. 1985. Weak mutagenicity to salmonella of the formaldehyde-releasing anti-tumour agent hexamethylmelamine. Mutat Res 142:121–125.3919288
*ASTER. 1995. ASTER (Assessment Tools for the Evaluation of Risk) ecotoxicity profile. Duluth, MN: Environmental Research Laboratory, U.S. Environmental Protection Agency.
*ASTER. 1996. ASTER (Assessment Tools for the Evaluation of Risk) ecotoxicity profile. Duluth, MN: Environmental Research Laboratory, U.S. Environmental Protection Agency.
*Atkinson R, Pitts JN J. 1978. Kinetics of the reactions of the OH radical with HCHO and CH_3_CHO over the temperature range 299–426 K. J Chem Phys 68:3581–3584.
*Atkinson R, Plum CN, Carter WP L, 1984. Rate constants for the gas-phase reactions of nitrate radicals with a series of organics in air at 298 +/− 1 K. J Phys Chem 88:1210–1215.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54:37617–37634.
ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction, Agency for Toxic Substances and Disease Registry, Atlanta, GA.
Babiuk C, Steinhagen WH, Barrow CS. 1985. Sensory irritation response to inhaled aldehydes after formaldehyde pretreatment. Toxicol Appl Pharmacol 79:143–149.4049401
*Bach B, Pedersen OF, Molhave Ll. 1990. Human performance during experimental formaldehyde exposure. Environ Int 16:105–113.
Baez AP, Padilla HG, Belmont RD. 1993. Scavenging of atmospheric formaldehyde by wet precipitation. Environ Pollut 79:271–275.15091889
Bagchi D, Bagchi M, Hassoun E, 1993a. Effects of carbon tetrachloride, menadione, and paraquat on the urinary excretion of malondialdehyde, formaldehyde, acetaldehyde, and acetone in rats. J Biochem Toxicol 8:101–106.8355259
Bagchi D, Bagchi M, Hassoun E, 1993b. Carbon-tetrachloride-induced urinary excretion of formaldehyde, malondialdehyde, acetaldehyde and acetone in rats. Pharmacology 47:209–216.
Bagchi DE, Stohs SJB M. 1992. Endrin-induced urinary excretion of formaldehyde, acetaldehyde, malondialdehyde and acetone in rats. Toxicology 75:81–89.1455427
*Ballarin C, Sarto F, Giacomelli L, 1992. Micronucleated cells in nasal mucosa of formaldehyde-exposed workers. Mutat Res 280:1–7.1377340
*Balmat JL, Meadows GW. 1985. Monitoring of formaldehyde in air. Am Ind Hyg Assoc J 46:578–584.4061288
Band PR, Le ND, Fang R, 1997. Cohort mortality study of pulp and paper mill workers in British Columbia, Canada. Am J Epidemiol 146:186–194.9230781
Banky Z, Nagy GM, Halasz B. 1994. Analysis of pituitary prolactin and adrenocortical response to ether, formalin or restraint in lactating rats: Rise in corticosterone, but no increase in plasma prolactin levels after exposure to stress. Neuroendocrinology 59:63–71.8145895
Bardana EJ, Montanaro A. 1991. Formaldehyde: an analysis of its respiratory, cutaneous, and immunologic effects. Ann Allergy 66:441–452.2048760
*Barnes DG, Dourson M. 1988. Reference dose (RfD) description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barry JL, Tome D. 1991. Formaldehyde content of milk in goats fed formaldehyde-treated soybean oil-meal. Food Addit Contam 8:633–640.1818837
*Bartnik FG, Gloxhuber C, Zimmermann V. 1985. Percutaneous absorption of formaldehyde in rats. Toxicol Lett 25:167–172.3923659
Bartone NF, Grieco RV, Herr BS. 1968. Corrosive gastritis due to ingestion of formaldehyde. JAMA, J Am Med Assoc 203:104–105.
*Barzana E, Klibanov AM, Karel M. 1989. A colorimetric method for the enzymatic analysis of gases: The determination of ethanol and formaldehyde vapors using solid alcohol oxidase. Anal Biochem 182:109–115.2690675
*Basler A, Hude VD, Hude W, 1985. Formaldehyde-induced sister chromatid exchanges in vitro and the influence of the exogenous metabolizing systems S9 mix and primary rat hepatocytes. Arch Toxicol 58:10–13.4074125
Bauchinger M, Schmid E. 1985. Cytogenetic effects in lymphocytes of formaldehyde workers of a paper factory. Mutat Res 58:195–199.
*Baumann K, Angerer J. 1979. Occupational chronic exposure to organic solvents. VI. Formic acid concentration in blood and urine as an indicator of methanol exposure. Int Arch Occup Environ Health 42:241–249.422265
Beall JE. 1985. Formaldehyde in dialysis patients: A review. Adv Chem Ser 210:276–286.
Becking GC. 1995. Use of mechanistic information in risk assessment for toxic chemicals. Toxicol Lett 7:15–24.
*Bedford P, Fox BW. 1981. The role of formaldehyde in methylene dimethanesulphonate-induced DNA cross-links and its relevance to cytotoxicity. Chem Biol Interact 38:119–126.7326803
*Bender JR, Mullin LS, Graepel GJ, 1983. Eye irritation response of humans to formaldehyde. Am Ind Hyg Assoc J 44:463–465.6881068
*Benner WH, Bizjak M. 1988. Pseudo first-order reaction rate constant for the formation of hydroxymethylhydroperoxide from formaldehyde and hydrogen peroxide. Atmos Environ 22:2603–2605.
Benyajati C, Place AR, Sofer W. 1983. Formaldehyde mutagenesis in Drosophila: Molecular analysis of ADH-negative mutants. Mutat Res 11:1–7.
Berglund B, Nordin S. 1992. Detectability and perceived intensity for formaldehyde in smokers and non-smokers. Chem Senses 17:291–306.
Berke JH. 1987. Cytologic examination of the nasal mucosa in formaldehyde-exposed workers. J Occup Med 29:681–684.3498808
Bermudez E. 1986. Assessment of genotoxic effects in rat nasal epithelium. In: Barrow CS, ed. Toxicology of the nasal passages. Washington, DC: Hemisphere Publishing Corporation, 275–290.
Bermudez E, Craft TR. 1987. Correlation of DNA-protein crosslinks (DPC) with cytotoxicity and mutagenicity in formaldehyde (HCHO) treated human lymphoblasts [Abstract]. Environ Mutagen 9:14.
Bermudez E, Chen Z, Gross EA, 1994. Characterization of cell lines derived from formaldehyde-induced nasal tumors in rats. Mol Carcinog 9:193–199.8148052
Bernstein RS, Stayner LT, Elliott LJ, 1984. Inhalation exposure to formaldehyde: An overview of its toxicology, epidemiology, monitoring, and control. Am Ind Hyg Assoc J 45:778–785.6391129
*Bertazzi PA, Pesatori A, Guercilena S, 1989. Rischio cancerogeno per I produttori di resine esposti a formaldeide: Estensione del follow-up. Med Lav 80:111–122. (Italian)2770616
*Bertazzi PA, Pesatori AC, Radice L, 1986. Exposure to formaldehyde and cancer mortality in a cohort of workers producing resins. Scand J Work Environ Health 12:461–468.3787218
Betterton EA, Hoffmann MR. 1988. Henry's law constants of some environmentally important aldehydes. Environ Sci Technol 22:1415–1418.22200466
*Bhalla DK, Mahavni V, Nguyen T, 1991. Effects of acute exposure to formaldehyde on surface morphology of nasal epithelia in rats. J Toxicol Environ Health 33:171–188.2051493
Bhatt HS, Lober SB, Combes B. 1988. Effect of glutathione depletion on aminopyrine and formaldehyde metabolism. Biochem Pharmacol 37:1581–1589.3358787
Bhatt HV, Panchal GM. 1992. Behavioral change in rats due to chronic oral and systemic formaldehyde. Indian J Physiol Pharmacol 36:270–272.1291481
*Bhattacharya SK, Parkin GF. 1988. Fate and effect of methylene chloride and formaldehyde in methane fermentation systems. J Water Pollut Control Fed 60:531–536.
Biagini RE, Moorman WJ, Knecht EA, 1989. Acute airway narrowing in monkeys from challenge with 2.5 ppm formaldehyde generated from formalin. Arch Environ Health 44:12–17.2644895
Bille H. 1981. [Formaldehyde in textile finishing - Is it necessary?]. Melliand Textilber 10:811–817. (German)
Binding N, Witting U. 1990. Exposure to formaldehyde and glutardialdehyde in operating theatres. Int Arch Occup Environ Health 62:233–238.2112118
*Blackburn GR, Dooley JF, Schreiner CA. 1991. Specific identification of formaldehyde mediated mutagenicity using the mouse lymphoma L5178Y TK +/− assay supplemented with formaldehyde dehydrogenase. In Vitro Toxicol 4:121–132.
Blackwell M, Kang H, Thomas A, 1981. Formaldehyde: Evidence of carcinogenicity. Am Ind Hyg Assoc J 42:34–46.
Blair A, Stewart PA. 1990. Correlation between different measures of occupational exposure to formaldehyde. Am J Epidemiol 131:510–516.2301359
*Blair A, Saracci R, Stewart PA, 1990a. Epidemiologic evidence on the relationship between formaldehyde exposure and cancer. Scand J Work Environ Health 16:381–393.2284588
*Blair A, Stewart P, O'Berg M, 1986. Mortality among industrial workers exposed to formaldehyde. J Natl Cancer Inst 76:1071–1084.3458945
*Blair A, Stewart PA, Hoover RN. 1990b. Mortality from lung cancer among workers employed in formaldehyde industries. Am J Ind Med 17:683–700.2343874
Boeniger MF. 1987. Formate in urine as a biological indicator of formaldehyde exposure: A review. Am Ind Hyg Assoc J 48:900–908.3321963
Bogndanffy MS, Morgan PH, Starr TB, 1987. Binding of formaldehyde to human and rat nasal mucus and bovine serum albumin. Toxicol Lett 38:145–154.3629625
*Boja JW, Nielsen JA, Foldvary E, 1985. Acute low-level formaldehyde behavioural and neurochemical toxicity in the rat. Prog Neuro-Psychopharmacol Biol Psychiat 9:671–674.
*Bolt HM. 1987. Experimental toxicology of formaldehyde. J Cancer Res Clin Oncol 113:305–309.3298280
*Bond GG, Flores GH, Shellenberger RJ, 1986. Nested case-control study of lung cancer among chemical workers. Am J Epidemiol 124:53–66.3717140
Bond JA. 1993. Metabolism and elimination of inhaled drugs and airborne chemicals from the lungs. Pharmacol Toxicol 72:36–47.8372063
Booz, Allen, Hamilton, Inc. 1979. Preliminary study of the costs of increased regulation of formaldehyde exposure in the US workplace. Prepared for Formaldehyde Task Force, Synthetic Organic Chemical Manufacturers Association, Fiorham Park, NJ. 3–30, 339–341, 359–364, 370–372.
*Boreiko CJ, Ragan DL. 1983. Formaldehyde effects in the C3H/10T½ cell transformation assay. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 63–71.
Bostrom C-E, Almen J, Steen B, 1994. Human exposure to urban air pollution. Environ Health Perspect 102:39–47.
*Boysen M, Zadig E, Digernes V, 1990. Nasal mucosa in workers exposed to formaldehyde: a pilot study. Br J Ind Med 47:116–121.2310715
*Bracken MJ, Leasa DJ, Morgan WK C. 1985. Exposure to formaldehyde: Relationship to respiratory symptoms and function. Can J Public Health 76:312–316.4084884
Braga PC. 1989. Agents that affect ciliary activity. In: Braga PC, Allegra L, ed. Drugs in bronchial mucology. New York, NY: Raven Press Ltd., 335–348.
Braga PC, Allegra L. 1989. Agents that modify glandular activity and mucus secretion. In: Braga PC, Allegra L, ed. Drugs in bronchial mucology. New York, NY: Raven Press, Ltd, 349–358.
Brandorff NP, Flyvhokm M-A, Beck ID, 1995. National survey on the use of chemicals in the working environment: Estimated exposure events. Occup Environ Med 52:454–463.7670620
Brandwein M, Pervez N, Biller H. 1987. Nasal squamous carcinoma in an undertaker - does formaldehyde play a role? Rhinology 25:279–284.3324283
*Brinton LA, Blot WJ, Becker JA, 1984. A case-control study of cancers of the nasal cavity and paranasal sinuses. Am J Epidemiol 119:896–906.6731431
*Brinton LA, Blot WJ, Fraumeni JF J. 1985. Nasal cancer in the textile and clothing industries. Br J Ind Med 42:469–474.4015994
Brockman HE, Yung CY, deSerres FJ. 1981. Potent mutagenicity of formaldehyde in a nucleotide excision repair-deficient heterokaryon of Neurospora crassa [Abstract]. Environ Mutagen 3:379–380.
Broder I, Corey P, Cole P, 1988a. Comparison of health of occupants and characteristics of houses among control homes and homes insulated with urea formaldehyde foam. II. Initial health and house variables and exposure-response relationships. Environ Res 45:156–178.3127198
Broder I, Corey P, Brasher P, 1988b. Comparison of health of occupants and characteristics of houses among control homes and homes insulated with urea formaldehyde foam. III. Health and house variables following remedial work. Environ Res 45:179–203.3349974
Broder I, Corey P, Brasher P, 1991. Formaldehyde exposure and health status in households. Environ Health Perspect 95:101–104.1821362
Brown BL, Allis JW, Simmons JE, 1995. Fasting for less than 24 h induces cytochrome P450 2E1 and 2B½ activities in rats. Toxicol Lett 81:39–44.8525497
Brown KG. 1985. Risk assessment of laboratory rats and mice chronically exposed to formaldehyde vapors. Risk Anal 5:171–180.3916550
Brown LP. 1989. Do rats comply with EPA policy on cancer risk assessment for formaldehyde? Regul Toxicol Pharmacol 10:196–200.2813872
*Brutlag D, Schlehuber C, Bonner J. 1969. Properties of formaldehyde-treated nucleohistone. Biochemistry 8:3214–3218.5809221
Bruze M. 1988. Patch testing with a mixture of 2 phenol-formaldehyde resins. Contact Dermatitis 19:116–119.2972520
Bruze M, Almgren G. 1988. Occupational dermatoses in workers exposed to resins based on phenol and formaldehyde. Contact Dermatitis 19:272–277.2975578
Buckley KE, Fisher L J, MacKay VG. 1986. Electron capture gas chromatographic determination of traces of formaldehyde in milk as the 2,4-dintrophenylhydrazone. J Assoc Off Anal Chem 69:655–657.3745094
*Buckley KE, Fisher LJ, MacKay VG. 1988. Levels of formaldehyde in milk, blood, and tissues of dairy cows and calves consuming formalin-treated whey. J Agric Food Chem 36:1146–1150.
*Budavari S, O'Neil MJ, Smith A, 1989. The Merck index. 11^th^ ed. Rahway, N.J.: Merck & Co., Inc.
Budiansky S. 1980. Indoor air pollution. Environ Sci Technol 14:1023–1027.
Bufalini JJ, B W. Gay Jr, Brubaker KL. 1972. Hydrogen peroxide formation from formaldehyde photooxidation and its presence in urban atmospheres. Environ Sci Technol 6:816–821.
*Bufalini JJ, Lancaster HT, Namie GR, 1979. Hydrogen peroxide formation from the photooxidation of formaldehyde and its presence in rainwater. J Environ Sci Health Part A 14:135–141.
*Burge PS, Harries MG, Lam WK, 1985. Occupational asthma due to formaldehyde. Thorax 40:255–260.4023975
Burkhart K, Kulig K, Rumack BH, 1989. Formate and methanol levels following formalin ingestion [Abstract]. Vet Hum Toxicol 31:375.
*Burkhart KK, Kulig KW, McMartin KE. 1990. Formate levels following a formalin ingestion. Vet Hum Toxicol 32:135–137.2327060
Burridge TR, Lavery T, Lam PK S. 1995a. Acute toxicity tests using Phyllospora comosa (labillardiere) c. agardh (phaeophyta: fucales) and Allorchestes compressa dana (crustacea: amphipoda). Bull Environ Contam Toxicol 55:621–628.8555690
Burridge TR, Lavery T, Lam PK S. 1995b. Effects of tributyltin and formaldehyde on the germination and growth of Phyllospora comosa (labillardiere) c. agardh (phaeophyta: fucales). Bull Environ Contam Toxicol 55:525–532.8555676
Bush ML, Frederick CB, Kimbell JS, 1998. A CFD-PBPK hybrid model for simulating gas and vapor uptake in the rat nose. Toxicol Appl Pharmacol 150:133–145.9630462
Butterworth BE, Conolly RB, Morgan KT. 1995. A strategy for establishing mode of action of chemical carcinogens as a guide for approaches to risk assessments. Cancer Lett 93:129–146.7600540
Cadet R, Pajot J, Papon A, 1998. Is there a correlation between scores of nociceptive behavioral responses to formalin injections given at different body sites in the rat? Neurosci Lett 242:123–126.9530921
Callas PW, Pastides H, Hosmer DW Jr. 1996. Lung cancer mortality among workers in formaldehyde industries. J Occup Environ Med 38:747–748.8863198
*Calvert JG, Kerr JA, Demerjian KL, 1972. Photolysis of formaldehyde as a hydrogen atom source in the lower atmosphere. Science 175:751–752.17836132
Cam V. 1985. Issues on health risk assessment a hazardous waste sites and resource recovery facilities in Region II. Toxicol Ind Health 1:271–276.3843507
Carlson FE, Phillips EK, Tenhaeff SC, 1995. A study of formaldehyde and other organic emissions from pressing of laboratory oriented strandboard. For Prod J 45:71–77.
Carpenter CP, Smyth HF. 1946. Chemical burns of the rabbit cornea. Am J Ophthalmol 29:1363–1372.20276971
*Carraro E, Gasparini S, Petrini T, 1997. Immune response prevalence to formaldehyde-human serum albumin molecular adduct in a health population. J Environ Pathol Toxicol Oncol 16:215–218.9276005
Carter WP L. 1990. A detailed mechanism for the gas-phase atmospheric reactions of organic compounds. Atmos Environ 24A:481–518.
*Casanova M, Heck Hd'A. 1987. Further studies of the metabolic incorporation and covalent binding of inhaled [^3^H]- and [^14^C] formaldehyde in Fischer-344 rats: Effects of glutathione depletion. Toxicol Appl Pharmacol 89:105–121.2438809
Casanova M, Heck Hd'A. 1991. The impact of DNA-protein cross-linking studies on quantitative risk assessments of formaldehyde. CIIT Act 11:1–6.
Casanova M, Heck Hd'A. 1997. Lack of evidence for the involvement of formaldehyde in the hepatocarcinogenicity of methyl tertiary-butyl ether in CD-1 mice. Chem Biol Interact 105:131–143.9251725
Casanova M, Conolly RB, Heck Hd'A. 1996a. DNA-protein cross-links (DPC) and cell proliferation in B6C3F_1_ mice but not Syrian golden hamsters exposed to dichloromethane: Pharmacokinetics and risk assessment with DPX as dosimeter. Fundam Appl Toxicol 31:103–116.8998946
*Casanova M, Deyo DF, Heck Hd'A. 1989. Covalent binding of inhaled formaldehyde to DNA in the nasal mucosa of Fischer 344 rats: Analysis of formaldehyde and DNA by high-performance liquid chromatography and provisional pharmacokinetic interpretation. Fundam Appl Toxicol 12:319–417.
*Casanova M, Deyo DF, Heck Hd'A. 1992. Dichloromethane (methylene chloride): Metabolism to formaldehyde and formation of DNA-protein cross links in B6C3F1 mice and Syrian golden hamsters. Toxicol Appl Pharmacol 114:162–165.1585369
*Casanova M, Heck Hd'A, Everitt JI, 1988. Formaldehyde concentrations in the blood of Rhesus monkeys after inhalation exposure. Food Chem Toxicol 26:715–716.3198038
Casanova M, Heck Hd'A, Janszen D. 1996b. Comments on 'DNA-protein crosslinks, a biomarker of exposure to formaldehyde-in vitro and in vivo studies' by Shaham et al. [Letter]. Carcinogenesis 17:2097–2101.8824543
*Casanova M, Morgan KT, Gross EA, 1994. DNA-protein cross-links and cell replication at specific sites in the nose of F344 rats exposed subchronically to formaldehyde. Fundam Appl Toxicol 23:525–536.7867904
*Casanova M, Morgan KT, Steinhagen WH, 1991. Covalent binding of inhaled formaldehyde to DNA in the respiratory tract of Rhesus monkeys: Pharmacokinetics, rat-to-monkey interspecies scaling, and extrapolation to man. Fundam Appl Toxicol 17:409–428.1765228
Casanova-Schmitz M, Heck H. 1983. Effects of formaldehyde exposure on the extractability of DNA from proteins in the rat nasal mucosa. Toxicol Appl Pharmacol 70:121–132.6193611
*Casanova-Schmitz M, Raymond MD, Heck Hd'A. 1984b. Oxidation of formaldehyde and acetaldehyde by NAD+-dependent dehydrogenases in rat nasal mucosal homogenates. Biochem Pharmacol 33:1137–1142.6477684
*Casanova-Schmitz M, Starr TB, Heck Hd'A. 1984a. Differentiation between metabolic incorporation and covalent binding in the labeling of macromolecules in the rat nasal mucosa and bone marrow by inhaled [^14^C]- and [^3^H] formaldehyde. Toxicol Appl Pharmacol 76:26–44.6207627
Cascieri TC, Clary JJ. 1992. Formaldehyde-oral toxicity assessment. Comments Toxicol 4:295–304.
Cassee FR, Feron VJ. 1993. Histopathological and biochemical changes in nasal epithelium of rats after 3-day intermittent exposure to a mixture of ozone and formaldehyde [Abstract]. Toxicol Lett 72:142.
Cassee FR, Arts JH E, Groten JP, 1996a. Sensory irritation to mixtures of formaldehyde, acrolein, and acetaldehyde in rats. Arch Toxicol 70:329–337.8975631
*Cassee FR, Groten JP, Feron VJ. 1996b. Changes in the nasal epithelium of rats exposed by inhalation to mixtures of formaldehyde, acetaldehyde, and acrolein. Fundam Appl Toxicol 29:208–218.8742318
Cassee FR, Stenhuis WH, Groten JP, 1996c. Toxicity of formaldehyde and acrolein mixtures: in vitro studies using nasal epithelial cells. Exp Toxicol Pathol 48:481–483.8954326
*Cassee R, Feron VJ. 1994. Biochemical and histopathological changes in nasal epithelium of rats after 3-day intermittent exposure to formaldehyde and ozone alone or in combination. Toxicol Lett 72:257–268.7911263
*Cassidy SL, Dix KM, Jenkins T. 1983. Evaluation of a testicular sperm head counting technique using rats exposed to dimethoxyethyl phthalate (DMEP), glycerol alpha-monochlorohydrin (GMCH), epichlorohydrin (ECH), formaldehyde (FA), or methyl methanesulphonate (MMS). Arch Toxicol 53:71–78.6882214
Casteel SW, Vernon RJ, Bailery EM. 1987. Formaldehyde: Toxicology and hazards. Vet Hum Toxicol 29:31–33.3824872
Castle ME. 1986. Silage: Pollution problems and their avoidance [Abstract]. Anim Prod 42:447.
*Chameides WL. 1986. Photochemistry of the atmospheric aqueous phase. In: Jaeschke W, ed. Chemistry of multiphase atmospheric systems. Berlin: Springer-Verlag, 369–413.
*Chameides WL, Davis DD. 1983. Aqueous-phase source of formic acid in clouds. Nature 304:427–429.
*Chan C-C, Spengler JD, Ozkaynak H, 1991. Commuter exposures to VOCs in Boston, Massachusetts. J Air Waste Manage Assoc 41:1594–1600.1799446
*Chang J-Y, Lin J-M. 1998. Aliphatic aldehydes and allethrin in mosquito-coil smoke. Chemosphere 36:617–624.9451813
*Chang JC F, Gross EA, Swenberg JA, 1983. Nasal cavity deposition, histopathology, and cell proliferation after single or repeated formaldehyde exposure in B6C3F1 mice and F-344 rats. Toxicol Appl Pharmacol 68:161–176.6857658
*Chang JC F, Steinhagen H, Barrow CS. 1981. Effect of single or repeated formaldehyde exposure on minute volume of B6C3F1 mice and F-344 rats. Toxicol Appl Pharmacol 61:451–459.7330883
*Chebotarev AN, Titenko NV, Selezneva TG, 1986. Comparison of the chromosome aberrations, sister chromatid exchanges, and unscheduled DNA synthesis when evaluating the mutagenicity of environmental factors. Cytol Genet 20:21–26.
Cheney JE, Collins CH. 1995. Formaldehyde disinfection in laboratories: limitations and hazards. Br J Biomed Sci 52:195–201.8527997
*Chiazze LJ, Watkins DK, Fryar C, 1993. A case-control study of malignant and non-malignant respiratory disease among employees of a fibreglass manufacturing facility. II: Exposure assessment. Br J Ind Med 50:717–725.8398858
Chiazze L Jr, Watkins DK, Fryar C. 1997. Historical cohort mortality study of a continuous filament fiberglass manufacturing plant. I. White men. J Occup Environ Med 39:432–441.9172088
*Chou C-C, Que Hee SS. 1994. Saliva-available carbonyl compounds in some chewing tobaccos. J Agric Food Chem 42:2225–2230.
*CIIT. 1998. Chemical Industry Institute of Toxicology. Formaldehyde risk assessment meeting. November 14, 1997. Research Triangle Park, NC.
Clement PA R, Stoop AP, Kaufman L. 1987. The influence of formaldehyde on the nasal mucosa. Rhinology 25:29–34.3576059
Clement RE, Langhorst ML, Eiceman GA. 1991. Environmental analysis. Anal Chem 63:270R–292R.
*Cleveland WS, Graedel TE, Kleiner B. 1977. Urban formaldehyde: Observed correlation with source emissions and photochemistry. Atmos Environ 11:357.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
Cocco P, Ward MH, Buiatti E. 1996. Occupational risk factors for gastric cancer: An overview. Epidemiol Rev 18:218–234.9021314
Coene RF. 1981. Formaldehyde: Evidence of carcinogenicity. Vet Hum Toxicol 23:282–285.
*Cofer WR, Edahl RA. 1986. A new technique for collection, concentration and determination of gaseous trophospheric formaldehyde. Atmos Environ 20:979–984.
*Coggon D, Pannett B, Acheson ED. 1984. Use of job-exposure matrix in an occupational analysis of lung and bladder cancers on the basis of death certificates. J Natl Cancer Inst 72:61–65.6363790
*Cohen MD, Miller CA, Xu LS, 1990. A blotting method for monitoring the formation of chemically induced DNA-protein complexes. Anal Biochem 186:1–7.2356961
Cohen MR. 1995. Insufficient dose of hepatitis B vaccine given to 1400 newborns; formalin accidents. Hosp Pharm 30:938–939.
Cohen N, Modai D, Khahil A, 1989. Acute resin phenol-formaldehyde intoxication. A life threatening occupational hazard. Hum Toxicol 8:247–250.2744783
*Cohen Hubal EA, Schlosser PM, Conolly RB, 1997. Comparison of inhaled formaldehyde dosimetry predictions with DNA-protein cross-link measurements in the rat nasal passages. Toxicol Appl Pharmacol 143:47–55.9073591
Cohn MS. 1985. Description of a carcinogenic risk assessment used in a regulatory proceeding: Formaldehyde. In: Hoel DG, Merrill RA, Perera FP, ed. Risk quantitation and regulatory policy. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 269–281.
Colizzo F, Krantz MJ, Fish JE, 1992. Ciliated respiratory epithelial surface changes after formaldehyde exposure. J Toxicol Environ Health 35:221–234.1533681
Colli M, Gironi A, Molina V, 1991. Improved HPLC methodology in occupational exposure studies on formaldehyde. Chromatographia 32:113–115.
*Collins JJ, Acquavella JF, Esmen NA. 1997. An updated meta-analysis of formaldehyde exposure and upper respiratory tract cancers. J Occup Environ Med 39:639–651.9253725
Collins JJ, Caporossi J C, Utidjian HM D. 1988. Formaldehyde exposure and nasopharyngeal cancer: Reexamination of the National Cancer Institute study and an update of one plant. J Natl Cancer Inst 80:376–377.3357202
Conaway CC, Whysner J, Verna LK, 1996. Formaldehyde mechanistic data and risk assessment: Endogenous protection from DNA adduct formation. Pharmacol Ther 71:29–55.8910948
*Connor TH, Barrie MD, Theiss JC, 1983. Mutagenicity of formalin in the Ames assay. Mutat Res 119:145–149.6338368
*Connor TH, Theiss JC, Hanna HA, 1985a. Genotoxicity of organic chemicals frequently found in the air of mobile homes. Toxicol Lett 25:33–40.3887653
*Connor TH, Ward JB, Legator MS. 1985b. Absence of mutagenicity in the urine of autopsy service workers exposed to formaldehyde: factors influencing mutagenicity testing of urine. Int Arch Occup Environ Health 56:225–237.4066051
*Conolly RB, Andersen ME. 1993. An approach to mechanism-based cancer risk assessment for formaldehyde. Environ Health Perspect Suppl 101:169–176.
Conolly RB, Andjelkovich DA, Casanova M, 1995. Multidisciplinary, iterative examination of the mechanism of formaldehyde carcinogenicity: The basis for better risk assessment. CIIT Act 15:1–10.
*Conolly RB, Morgan KT, Andersen ME, 1992. A biologically-based risk assessment strategy for inhaled formaldehyde. Comments Toxicol 4:269–293.
Contreras KM, Larsen SJ V, Harris C. 1996. Differential in vitro toxicity of mouse and rat embryos following direct intra-amniotic exposure to methanol, form-aldehyde and sodium formate [Abstract]. Toxicologist 30:194.
Coon RA, Jones RA, Jenkins LJ Jr, 1970. Animal inhalation studies on ammonia, ethylene, glycol, formaldehyde, dimethylamine and ethanol. Toxicol Appl Pharmacol 16:646–655.4987187
Cooper JR, Kini MM. 1962. Biochemical aspects of methanol poisoning. Biochem Pharmacol 11:405–416.13881150
Cosma GN, Marchok AC. 1986. Growth inhibition and DNA damage in rat tracheal epithelial cells exposed to benzo(a)pyrene and formaldehyde (HCHO) [Abstract]. J Cell Biol 103:173a.
Cosma GN, Marchok AC. 1987. The induction of growth-altered cell populations (tumor-initiation sites) in rat tracheal implants exposed to benzo(a)pyrene and formaldehyde. Carcinogenesis 8:1951–1953.3677320
*Cosma GN, Marchok AC. 1988. Benzo[a]pyrene- and formaldehyde-induced DNA damage and repair in rat tracheal epithelial cells. Toxicology 51:309–320.3176033
*Cosma GN, Jamabi R, Marchok AC. 1988a. Growth inhibition and DNA damage induced by benzo[a]pyrene and formaldehyde in primary cultures of rat tracheal epithelial cells. Mutat Res 201:161–168.3419444
Cosma GN, Wilhite AS, Marchok AC. 1988b. In vivo detection of DNA-protein crosslinks in rat tracheal implants exposed to benzo(a)pyrene (BAP) and formaldehyde (HCHO) [Abstract]. Proc Am Assoc Cancer Res 29:108.
Cosma GN, Wilhite AS, Marchok AC. 1988c. The detection of DNA-protein cross-links in rat tracheal implants exposed in vivo to benzo(a)pyrene and formaldehyde. Cancer Lett 42:13–21.3180031
Costa M, Zhitkovich A, Harris M, 1997. DNA-protein cross-links produced by various chemicals in cultured human lymphoma cells. J Toxicol Environ Health 50:433–449.9140463
Costantini AS, Paci E, Miligi L, 1989. Cancer mortality among workers in the Tuscan tanning industry. Br J Ind Med 46:384–388.2818971
Couch DB, Allen PF, Eales HC. 1982. The mutagenicity of formaldehyde to Salmonella typhimurium [Abstract]. Environ Mutagen 4:336–337.
Council on Scientific Affairs. 1989. Formaldehyde. JAMA,J Am Med Assoc 261:1183–1187.
*CPSC. 1997. An update on formaldehyde. Washington, DC: U.S. Consumer Product Safety Commission.
Craft TR, Bermudez E, Skopek TR. 1987. Formaldehyde mutagenesis and formation of DNA-protein crosslinks in human lymphoblasts in vitro. Mutat Res 176:147–155.3796657
Cronin E. 1991. Formaldehyde is a significant allergen in women with hand eczema. Contact Dermatitis 25:276–282.1809530
Crosby RM, Richardson KK, Craft TR, 1988. Molecular analysis of formaldehyde-induced mutations in human lymphoblasts and e. coli. Environ Mol Mutagen 12:155–166.2900762
Crump DR. 1995. Volatile organic compounds in indoor air. In: Volatile organic compounds in the atmosphere. Cambridge: Royal Society of Chemistry, 109–124.
Crump DR, Squire RW, Yu CW F. 1997. Sources and concentrations of formaldehyde and other volatile organic compounds in the indoor air of four newly built unoccupied test houses. Indoor Built Environ 6:45–55.
*Daggett DL, Stock TH. 1985. An investigation into the storage stability of environmental formaldehyde samples. Am Ind Hyg Assoc J 46:497–504.
Dahl AR, Hadley WM. 1983. Formaldehyde production promoted by rat nasal cytochrome P-450-dependent monooxygenases with nasal decongestants, essences, solvents, air pollutants, nicotine, and cocaine as substrates. Toxicol Appl Pharmacol 67:200–205.6188239
*Dalbey WE. 1982. Formaldehyde and tumors in hamster respiratory tract. Toxicology 27:9–14.
*Dalene M, Persson P, Skarping G. 1992. Determination of formaldehyde in air by chemisorption on glass filters impregnated with 2,4-dinitrophenylhydrazine using gas chromatography with thermionic specific detection. J Chromatogr 626:284–288.
Dallas CE, Badeaux P, Theiss JC, 1989. The influence of inhaled formaldehyde on rat lung cytochrome P450. Environ Res 49:50–59.2721477
Dallas CE, Mellard DN, Theiss JC, 1987. Distribution of DNA and RNA content in the bone marrow and alveolar macrophages of rats after subchronic inhalation of formaldehyde. Environ Res 43:191–202.2438128
*Dallas CE, Scott MJ, Ward JB Jr, 1992. Cytogenetic analysis of pulmonary lavage and bone marrow cells of rats after repeated formaldehyde inhalation. J Appl Toxicol 12:199–203.1378462
*Dallas CE, Theiss JC, Harrist RB, 1985. Effect of subchronic formaldehyde inhalation on minute volume and nasal deposition in Sprague-Dawley rats. J Toxicol Environ Health 16:553–564.4087319
*Dallas CE, Theiss JC, Harrist RB, 1986. Respiratory responses in the lower respiratory tract of Sprague-Dawley rats to formaldehyde inhalation. J Environ Pathol Toxicol Oncol 6:1–12.
Dally KA, Hanrahan LP, Woodbury MA, 1981. Formaldehyde exposure in nonoccupational environments. Arch Environ Health 36:277–284.7316564
*Day JH, Lees RE M, Clark RH, 1984. Respiratory response to formaldehyde and off-gas of urea formaldehyde foam insulation. Can Med Assoc J 131:1061–1065.6388780
Deal FH, Swenberg JA, Fennell TR. 1989. Detection of hydroxymethyl adducts in deoxyribonucleosides, calf thymus DNA from isolated rat liver nuclei treated with formaldehyde [Abstract]. Carcinogenesis 30:131.
*Dean JH, Lauer LD, House RV, 1984. Studies of immune function and host resistance B6C3CLF1 mice exposed to formaldehyde. Toxicol Appl Pharmacol 72:519–529.6424265
DeAndrade JB, Tanner RL. 1992. Determination of formaldehyde by HPLC as the DNPH derivative following high-volume air sampling onto bisulfite-coated cellulose filters. Atmos Environ 26:819–825.
Dearman RJ, Smith S, Basketter DA, 1996. Classification of chemical allergens according to cytokine secretion profiles murine lymph node cells. J Appl Toxicol 17:53–62.
Dechow M, Sohn H, Steinhanses J. 1997. Concentrations of selected contaminants in cabin air of airbus aircrafts. Chemosphere 35:21–31.9231999
*De Flora S. 1981. Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis 2:283–298.7023727
*De Flora S, Zanacchi P, Camoirano A, 1984. Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test. Mutat Res 133:161–198.6374443
DeGroot AC, Gerkens F. 1989. Contact urticaria from a chemical textile finish. Contact Dermatitis 20:63–64.2914438
DeGroot AC, Bos JD, Jagtman BA, 1986. Contact allergy to preservatives - II. Contact Dermatitis 15:218–222.3492332
*DeGroot AC, VanJoost T, Bos JD, 1988. Patch test reactivity to DMDM hydantoin: Relationship to formaldehyde allergy. Contact Dermatitis 18:197–201.3378426
*Dekant W, Vamvakas S. 1993. Glutathione-dependent bioactivation of xenobiotics. Xenobiotica 23:873–887.8284943
Dell L, Teta MJ. 1995. Mortality among workers at a plastics manufacturing and research and development facility: 1946–1988. Am J Ind Med 28:373–384.7485191
*Dempsey CR. 1993. A comparison of organic emissions from hazardous waste incinerators versus the 1990 Toxics Release Inventory air releases. J Air Waste Manage Assoc 43:1374–1379.
Denton RA, Parker JE, Abrons HL, 1988. Lack of relationship between low levels of formaldehyde and airway hyperreactivity or changes in ventilatory function: A prospective study [Abstract]. Am Rev Respir Dis 137:299.
Dicker E, Cederbaum AI. 1987. Pathways of metabolism of formaldehyde produced from the oxidation of aminopyrine by intact rat hepatocytes. Ann N Y Acad Sci 494:332–335.
Dillon HK, Gao P. 1994. Laboratory evaluation of a novel reactive passive sampler for the quantitative determination of formaldehyde in air. Am Ind Hyg Assoc J 55:1061–1068.
*Dinsdale D, Riley RA, Verschoyle RD. 1993. Pulmonary cytochrome P450 in rats exposed to formaldehyde vapor. Environ Res 62:19–27.8100769
Doman NG, Romanova AK, Terent'eva ZA. 1961. [Conversion of some volatile organic substances absorbed by leaves from the atmosphere.]. Dokl Akad Nauk SSSR 138:702–705. (Russian)
*Dong S, Dasgupta PK. 1986. Solubility of gaseous formaldehyde in liquid water and generation of trace standard gaseous formaldehyde. Environ Sci Technol 20:637–640.19994964
*Dong S, Dasgupta PK. 1987. Fast fluorometric flow injection analysis of formaldehyde in atmospheric water. Environ Sci Technol 21:581–588.19994979
*Donovan SM, Krahn DF, Stewart JA, 1983. Mutagenic activities of formaldehyde (HCHO) and hexamethylphosphoramide (HMPA) in reverse and forward Salmonella typhimurium mutation assays [Abstract]. Environ Mutagen 5:476.
*DOT. 1980. Chemical kinetic and photochemical data sheets for atmospheric reactions. Washington, DC: U.S. Department of Transportation. AD A 091 631, FAA-EE-80–17.
Dowd MA, Gaulden ME, Proctor BL, 1986. Formaldehyde-induced acetric chromosome fragments and chromosome stickiness in Chortophaga neuroblasts. Environ Mutagen 8:401–411.3709425
*Dreisbach RH, Robertson WO. 1987. Esters, aldehydes, ketones & ethers. In: Dreisbach RH, Robertson WO, ed. Handbook of poisoning: prevention, diagnosis & treatment. Norwalk, CT: Appleton & Lange, 180–188.
*Dresp J, Bauchinger M. 1988. Direct analysis of the clastogenic effect of formaldehyde in unstimulated human lymphocytes by means of the premature chromosome condensation technique. Mutat Res 204:349–352.2449611
Dulany MA, Batten GL J, Peck MC, 1996. Papermaking additives. In: Howe-Grant M, ed. Kirk-Othmer encyclopedia of chemical technology. New York: John Wiley & Sons, Inc., 35–60.
Dumont M, D'Hont C, Moreal A, 1996. Retrograde injections of formaldehyde into the biliary tree induce alterations of biliary epithelial function in rats. Hepatology 24:1217–1223.8903401
Du Vigneaud V, Verly WG, Wilson JE. 1950. Incorporation of the carbon of formaldehyde and formate into the methyl groups of choline. J Am Chem Soc 72:2819–2820.
*Dykewicz MS, Patterson R, Cugell DW, 1991. Serum IgE and IgG to formaldehyde-human serum albumin: Lack of relation to gaseous formaldehyde exposure and symptoms. J Allergy Clin Immunol 87:48–57.1991923
Ebeler SE, Hinrichs SH, Clifford AJ, 1992. Analysis of reactive carbonyls in the expired air of transgenic mice. Anal Biochem 205:183–186.1443556
*Eberlein-Konig B, Przybilla B, Kuhnl P, 1998. Influence of airborne nitrogen dioxide or formaldehyde on parameters of skin function and cellular activation in patients with atopic eczema and control subjects. J Allergy Clin Immunol 101:141–143.9449520
*ECETOC. 1995. Technical Report No. 65. Formaldehyde and human cancer risk. Brussels, Belgium: ECETOC.
Echt A, Burr G. 1997. Exposure to formaldehyde during garment manufacturing. Appl Occup Environ Hyg 12:451–455.
Edling C, Hellquist H, Odkvist L. 1987a. Occupational formaldehyde exposure and the nasal mucosa. Rhinology 25:181–187.3672002
Edling C, Jarvholm B, Andersson L, 1987b. Mortality and cancer incidence among workers in an abrasive manufacturing industry. Br J Ind Med 44:57–59.3814536
*Edling C, Hellquist H, Odkvist L. 1988. Occupational exposure to formaldehyde and histopathological changes in the nasal mucosa. Br J Ind Med 45:761–765.3203081
Edman B, Moller H. 1982. Trends and forecasts for standard allergens in a 12-year patch test material. Contact Dermatitis 8:95–104.7067453
*Eells JT, McMartin KE, Black K, 1981. Formaldehyde poisoning: Rapid metabolism to formic acid. JAMA,J Am Med Assoc 246:1237–1238.
*Egle JL. 1972. Retention of inhaled formaldehyde, propionaldehyde, and acrolein in the dog. Arch Environ Health 25:119–124.5045063
*Egle JL, Hudgins PM. 1974. Dose-dependent sympathomimetic and cardioinhibitory effects of acrolein and formaldehyde in the anesthetized rat. Toxicol Appl Pharmacol 28:358–366.4851432
Egle JL J, Hudgins PM, Lai FM. 1973. Cardiovascular effects of intravenous acetaldehyde and propionaldehyde in the anesthetized rat. Toxicol Appl Pharmacol 24:636–644.4713486
Ehling UH. 1985. Dose-effect relationships of germ cell mutations in mice [Abstract]. Mutat Res 147:279–327.
Eikmann T, Prajsnar D, Einbrodt HJ. 1987. Quantitative estimation of formaldehyd exposure in normal population collectives on the basis of the formic acid excretion in urine [Abstract]. Zentralbl Bakteriol Mikrobiol Hyg [B] 183:483–484.
*Eitzer BD, Iannucci-Berger WA, Mark G, 1997. Fate of toxic compounds during composting. Bull Environ Contam Toxicol 58:953–960.9136660
Eker P, Sanner T. 1980. Initiation of in vitro cell transformation by formaldehyde and acetaldehyde as measured by attachment-independent survival of cells in aggregates. Eur J Cancer Clin Oncol 22:671–676.
*Ellenhorn MJ, Barceloux DG. 1988. Hydrocarbon products. In: Ellenhorn MJ, Barceloux DG, ed. Medical toxicology: diagnosis and treatment of human poisoning. New York: Elsevier, 1001–1004.
Ellwood PA, Groves JA, Pengelly MI. 1990. Evaluation of a diffuse sampler for formaldehyde. Ann Occup Hyg 34:305–313.2372191
ElSayed F, Seite-Bellezza D, Sans B, 1995. Contact urticaria from formaldehyde in a root-canal dental paste. Contact Dermatitis 33:353.
Endres P. 1992. [Effects of airborne pollutants on the respiratory tract]. In: Akkermann R, Behrends HB, Ehrnsberger R, ed. [Allergy and the environment: Medical and ecological contributions]. Cloppenburg, Germany: Verlag Guenter Runge, 105–114. (German)
Engelhardt G, Fleig I, Helmstadter G. 1987. Letter to the editor. Mutat Res 180:131–133.3627137
*EPA. 1975. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1032.
*EPA. 1976a. Investigation of selected potential environmental contaminants: Formaldehyde. U.S. Environmental Protection Agency, Office of Toxic Substances. PB 256 839, EPA-560/2–76-009.
*EPA. 1976b. Frequency of organic compounds identified in water. Athens, GA: U.S. Environmental Protection Agency, Environmental Research Laboratory, Office of Research and Development. EPA-600/4–76-062.
*EPA. 1977a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 86.
*EPA. 1977b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 176.170.
*EPA. 1977c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 176.180.
*EPA. 1978. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1979. Chemical Hazard Information Profile: Formaldehyde. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances. Draft edition. (November 26, 1979)
*EPA. 1980. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1981. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VII.
*EPA. 1982. Atmospheric chemistry of several toxic compounds. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research Laboratory, Office of Research and Development. PB83–146340, EPA-600/3–82-092.
*EPA. 1983a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.489.
*EPA. 1983b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122, Appendix D.
*EPA. 1984. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 125.
*EPA. 1985a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4
*EPA. 1985b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
*EPA. 1985c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266.112.
*EPA. 1986a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.10.
*EPA. 1986b. U. S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.42.
*EPA. 1987a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414.60.
*EPA. 1987b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.4.
*EPA. 1987c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A.
*EPA. 1987d. Assessment of health risks to garment workers and certain home residents from exposure to formaldehyde. U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*EPA. 1988a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.
*EPA. 1988b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
*EPA. 1988c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1988d. Compendium of methods for determination of toxic organic compounds in ambient air. U.S. Environmental Protection Agency. EPA-600/4–89/017.
*EPA. 1988e. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. PB88–179874.
*EPA. 1990a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.617.
*EPA. 1990b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.667.
*EPA. 1990c. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA-600/8–90/066A.
*EPA. 1991a. Formaldehyde risk assessment update - final draft. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
*EPA. 1991b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix IX.
*EPA. 1991c. Locating and estimating air emissions from sources of formaldehyde (revised). Research Triangle Park, NC: U.S. Environmental Protection Agency. PB91–181842, EPA-450/4–91-012.
EPA. 1991d. Urban air toxics monitoring program carbonyl results, 1990. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB92–110030, EPA-450/4–91-025.
*EPA. 1992a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.3.
*EPA. 1992b. Methods for determination of organic compounds in drinking water. U.S. Environmental Protection Agency. EPA-600/R-92/129.
*EPA. 1992c. National Air Toxics Information Clearinghouse: NATICH data base report on state, local, and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards.
*EPA. 1993a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.707.
*EPA. 1993b. U.S. Environmental Protection Agency. NESHAP for source category; pulp and paper production. Proposed rule. Federal Register 58:66078.
*EPA. 1993c. U.S. Environmental Protection Agency. List of regulated substances and thresholds for accidental release prevention. Federal Register 58:5102.
*EPA. 1993d. U.S. Environmental Protection Agency. Control of air pollution from new and in use motor vehicles and engines; technical amendments to the test procedures for methanol-fueled motor vehicles and motor vehicle engines and petroleum-fueled motor vehicles. Proposed rule. Federal Register 58:11816.
EPA. 1993e. U.S. Environmental Protection Agency. Land disposal restrictions for newly identified and listed hazardous wastes and hazardous soil. Federal Register 58:48092.
*EPA. 1994a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63.106.
*EPA. 1994b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68.130.
*EPA. 1994c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.42.
*EPA. 1994d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.45.
*EPA. 1994e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.51.
*EPA. 1994f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.56.
*EPA. 1994g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 80.90.
*EPA. 1994h. U.S. Environmental Protection Agency. HAP: proposed regulations governing constructed, reconstructed or modified major sources. U.S. Environmental Protection Agency. Federal Register 59:15504.
*EPA. 1994i. U.S. Protection Agency. Hazardous waste management system; carbamate production identification and listing of hazardous waste and CERCLA hazardous substance designation and reportable quantities. Notice of Proposed Rulemaking--K157 waste. Federal Register 59:9808.
EPA. 1994j. U.S. Environmental Protection Agency. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: Environmental Criteria and Assessment Office, Office of Health and Exposure Assessment, Office of Research and Development. EPA/600/8–90-066F.
*EPA. 1995. Drinking water regulations and health advisories. U.S. Environmental Protection Agency, Office of Water.
*EPA. 1996. Sources and factors affecting indoor emission from engineered wood products: Summary and evaluation of current literature. Research Triangle Park, NC: U.S. Environmental Protection Agency, National Risk Management Research Laboratory, Office of Research and Development. PB96–183876, EPA-600/R-96–067.
*EPA. 1997. U.S. Environmental Protection Agency. Federal Register. 62:7502.
Estlander T, Jolanki R, Kanerva L, 1990. An artist’s allergy to reactive dyes and formaldehyde [Abstract]. Contact Dermatitis 23:271–272.
Everitt JI, Boreiko CJ, Mangum JB, 1989. Development of a tracheal implant xenograft model to expose human bronchial epithelial cells to toxic gases. Toxicol Pathol 17:465–473.2814223
*Facchini MC, Lind J, Orsi G, 1990. Chemistry of carbonyl compounds in Po Valley fog water. Sci Total Environ 91:79–86.
*Fan Q, Dasgupta PK. 1994. Continuous automated determination of atmospheric formaldehyde at the parts per trillion level. Anal Chem 66:551–556.
Farooqui M Y.H, Upreti RK, Ahmed AE, 1986. Influence of intraperitoneally administered formaldehyde on bile production and tissue glutathione levels in rats. Res Commun Chem Pathol Pharmacol 53:233–240.3764085
Fayerweather WE, Pell S, Bender JR. 1983. Case control study of cancer deaths in DuPont workers with potential exposure to formaldehyde (retrieval in progress). In: Clary JJ, Gibson E, Weritz RS, ed. Formaldehyde: Toxicology, epidemiology, mechanisms. New York, NY: Marcel Dekker, Inc., 47–125.
*FDA. 1976. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 573.460.
*FDA. 1977a. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105.
FDA. 1977b. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 176.170.
FDA. 1977c. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 176.180.
*FEDRIP. 1996. Federal Research in Progress. Dialog Information Services, Incorporated. October, 1995.
Feinman SE. 1988. Formaldehyde genotoxicity and teratogenicity. In: Feinman SE, ed. Formaldehyde sensitivity and toxicity. Boca Raton, FL: CRC Press, 167–178.
Feldman MY. 1976. Reactions of nucleic acids and nucleoproteins with formaldehyde. Prog Nucleic Acid Res Mol Biol 13:1–49.
Feldman MY, Balabanova H, Bachrach U, 1977. Effect of hydrolyzed formaldehyde-treated RNA on neoplastic and normal human cells. Cancer Res 37:501–506.556680
*Fennell TR. 1994. Development of methods for measuring biological markers of formaldehyde exposure. Res Rep Health Eff Inst 67:1–26.
Fennell TR, Deal FH, Swenberg JA. 1988. Cross-linked adducts formed on reaction of formaldehyde with amino acids or glutathione, and deoxyribonucleosides or DNA [Abstract]. Proc Am Assoc Cancer Res 29:88.
*Feron VJ, Bruyntjes JP, Woutersen RA, 1988. Nasal tumours in rats after short-term exposure to a cytotoxic concentration of formaldehyde. Cancer Lett 39:101–111.3345504
*Feron VJ, Til HP and Woutersen RA. 1990. Letter to the Editor. Toxicol Ind Health 6:237–239.
*Feron VJ, Til HP, de Vrijer F, 1991. Aldehydes: occurrence, carcinogenic potential, mechanism of action and risk assessment. Mutat Res 259:363–385.2017217
*Ferry DG, Temple WA, McQueen EG. 1980. Methanol monitoring: Comparison of urinary methanol concentration with formic acid excretion rate as a measure of occupational exposure. Int Arch Occup Environ Health 47:155–163.7440001
Finlayson-Pitts BJ, Pitts JN J. 1993. Atmospheric chemistry of tropospheric ozone formation: Scientific and regulatory implications. J Air Waste Manage Assoc 43:1091–1100.
*Fischer T, Andersen K, Bengesson U, 1995. Clinical standardization of the TRUE Test formaldehyde patch. Curr Probl Dermatol 22:24–30.7587329
*Fishbein L. 1992. Exposure from occupational versus other sources. Scand J Work Environ Health 18:5–16.
*Fleig I, Petri N, Stocker WG, 1982. Cytogenetic analyses of blood lymphocytes of workers exposed to formaldehyde in formaldehyde manufacturing and processing. J Occup Med 24:1009–1012.7153801
*Fleisher JM. 1987. Medical students' exposure to formaldehyde in gross anatomy laboratories. N Y State J Med 87:385–388.3476866
Florence E, Milner DF. 1981. Determination of free and loosely protein-bound formaldehyde in the tissues of pigs fed formalin-treated skim milk as a protein supplement. J Sci Food Agric 32:288–292.7230743
*Flyvholm MA. 1991. Contact allergens in registered chemical products. Contact Dermatitis 25:49–56.1834412
*Flyvholm M-A, Hall BM, Agner T, 1997. Threshold for occluded formaldehyde patch test in formaldehyde-sensitive patients: Relationship to repeated open application test with a product containing formaldehyde releaser. Contact Dermatitis 36:26–33.9034684
Fontignie-Houbrechts N. 1981. Genetic effects of formaldehyde in the mouse. Mutat Res 88:109–114.7207492
Fontignie-Houbrechts N, Moutschen-dahmen M, Degraeve N, 1982. Genetic effects in the mouse of formaldehyde in combination with adenosine and hydrogen peroxide. Mutat Res 104:371–376.7110172
*Fomon SJ. 1966. Body composition of the infant. Part I: The male reference infant. In: Falkner F, ed. Human Development. Philadelphia, PA:WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Fowler JF, Skinner SM, Belsito DV. 1992. Allergic contact dermatitis from formaldehyde resins in permanent press clothing: An underdiagnosed cause of generalized dermatitis. J Am Acad Dermatol 27:962–968.1479102
Frakes RA, Sharma RP, Willhite CC. 1986. Comparative metabolism of linamarin and amygdalin in hamsters. Food Cosmet Toxicol 24:417–420.
Franke JP, Wijsbeek J, deZeeuw RA, 1988. Systematic analysis of solvents and other volatile substances by gas chromatography. J Anal Toxicol 12:20–24.3352238
*Frazelle JH, Abernethy DJ, Boreiko CJ. 1983. Weak promotion C3H/10T½ cell transformation by repeated treatments with formaldehyde. Cancer Res 43:3236–3239.6850633
*Freestone J, Bentley A. 1989. Case of formaldehyde poisoning. Br J Pharm Pract 11:20–21.
Freidman G D, Ury HK. 1983. Screening for possible drug carcinogenicity: Second report of findings. J Natl Cancer Inst 71:1165–1175.6581357
French D, Edsall JT. 1945. The reactions of formaldehyde with amino acids and proteins. Adv Protein Chem 2:277–335.
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. U.S. Environmental Protection Agency. Chemical Communications Subcommittee, Federal State Toxicology and Regulatory Alliance Committee.
Fugas M. 1985. [Radon and formaldehyde the conclusions and recommendations of WHO]. Zast Atmos 13:134–135. (Russian)
Fuji T, Tonomura K. 1972. Oxidation of methanol, formaldehyde and formate by a candida species. Agric Biol Chem 36:2297–2306.
Fujimaki H, Imai T, Befus D. 1992a. Mast cell response to formaldehyde: 2. Induction of stress-like proteins. Int Arch Allergy Immunol 98:332–338.1384865
Fujimaki H, Kawagoe A, Bissonnette E, 1992b. Mast cell response to formaldehyde: 1. Modulation of mediator release. Int Arch Allergy Immunol 98:324–331.1384864
Furihata C, Yamakoshi A, Matsushima T. 1988. Inductions of ornithine decarboxylase and DNA synthesis in rat stomach mucosa by formaldehyde. Jpn J Cancer Res 79:917–920.3141327
Furuta R, Doi T. 1994. Chiral separation of diniconazole, uniconazole and structurally related compounds by cyclodextrin-modified micellar electrokinetic chromatography. Electrophoresis 15:1322–1325.7895726
*Gaffney JS, Marley NA, Martin RS, 1997. Potential air quality effects of using ethanol-gasoline fuel blends: A field study in Albuquerque, New Mexico. Environ Sci Technol 31:3053–3061.
Gailhofer G, Binder H. 1988. Allergic contact dermatitis caused by an acetone-formaldehyde condensate. Contact Dermatitis 18:110–111.2966698
*Galli CL, Ragusa C, Resmini P, 1983. Toxicological evaluation in rats and mice of the ingestion of a cheese made from milk with added formaldehyde. Food Chem Toxicol 21:313–317.6407928
Galloway JN, Artz RS, Dayan U, 1988. WATOX-85: An aircraft and ground sampling program to determine the transport of trace gases and aerosols across the western Atlantic Ocean. Atmos Environ 22:2345–2360.
*Galloway SM, Bloom AD, Resnick M, 1985. Development of standard protocol for in vitro cytogenetic testing with Chinese hamster ovary cells: Comparison of results of 22 compounds in two laboratories. Environ Mutagen 7:1–51.
*Gammage RB, Hawthorne AR. 1985. Current status of measurement techniques and concentrations of formaldehyde in residences. In: Jacobs VA, ed. Indoor air and human health. New York, NY: Lewis Publishers, Inc., 117–130.
*Gannon PF G, Campbells M, O'Hickey SP, 1995. Occupational asthma due to glutaraldehyde and formaldehyde in endoscopy and x ray departments. Thorax 50:156–159.7701454
Garcia JP, Beyne-Masclet S, Mouvier G. 1992. Emissions of volatile organic compounds by coal-fired power stations. Atmos Environ 26A:1589–1597.
Garcia Bracamonte B, Ortiz de Frutos FJ, Iglesias Diez L. 1995. Occupational allergic contact dermatitis due to formaldehyde and textile finish resins. Contact Dermatitis 33:139–140.8549144
*Gardner MJ, Pannett B, Winter PD, 1993. A cohort study of workers exposed to formaldehyde in the British chemical industry: an update. Br J Ind Med 50:827–834.8398877
*Garry VF, Kreiger RA, Wiencke JK. 1981. The mutagenic and cytotoxic effects of formaldehyde in cultured human lymphocytes [Abstract]. Environ Mutagen 3:341.
*Garry VF, Oatman L, Pleus R, 1980. Formaldehyde in the home: Some environmental disease perspectives. Minn Med 63:107–111.7382970
Gaylor DW. 1983. Mathematical approaches to risk assessment: Squamous cell nasal carcinoma in rats exposed to formaldehyde vapor. In: Gibson JE, ed. Formaldehyde Toxicity. Washington, DC: Hemisphere Publishing Corporation, 279–283.
Gaylor DW. 1992. Incidence of developmental defects at the no observed adverse effect level (NOAEL). Regul Toxicol Pharmacol 15:151–160.1626066
Geier J, Lessmann H, Schnuch A, 1997. [Contact allergy due to formaldehyde-releasing biocides]. Allergologie 20:215–224. (German).
*Gerberich HR, Stautzenberger AL, Hopkins WC. 1980. Formaldehyde. In: Kirk-Othmer Encyclopedia of chemical technology. New York, NY: John Wiley & Sons, 231–250.
Gerhold RM, Malaney GW. 1966. Structural determinants in the oxidation of aliphatic compounds by activated sludge. J Water Pollut Control Fed 38:562–579.
*Gerin M, Siemiatcki J, Nadon L, 1989. Cancer risks due to occupational exposure to formaldehyde: Results of a multi-site case-control study in Montreal, Canada. Int J Cancer 44:53–58.2744897
Gescher A, Hickman JA, Stevens MF G. 1979. Oxidative metabolism of some n-methyl containing xenobiotics can lead to stable progenitors of formaldehyde. Biochem Pharmacol 28:3235–3238.575045
*Glass LR, Connor TH, Theiss JC, 1986. Genotoxic evaluation of the offgassing products of particle board. Toxicol Lett 31:75–83.3520959
*Glaze WH, Koga M, Cancilla D. 1989. Ozonation byproducts 2. Improvement of an aqueous phase derivatization method for detection of formaldehyde and other carbonyl compounds formed by the ozonation of drinking water. Environ Sci Technol 23:838–847.
Godish T. 1989. Formaldehyde exposures from tobacco smoke: A review. Am J Public Health 79:1044–1045.2665532
Godish T, Fell J, Lincoln P. 1984. Formaldehyde levels in New Hampshire urea - formaldehyde foam insulated houses. Relationship to outdoor temperature. J Air Pollut Control Assoc 34:1051–1052.
Goering PL. 1989. Acute exposure to formaldehyde induces hepatic metallothionein synthesis in mice. Toxicol Appl Pharmacol 98:325–337.2711395
*Gold KW, Naugle DF, Berry MA. 1993. Indoor concentrations of environmental carcinogens. In: Seifert B, van de Wiel HJ, O'Neill IK, ed. Environmental carcinogens: Methods of analysis and exposure measurement (IARC Scientific Publications No. 109). Lyon: International Agency for Research on Cancer, 41–71.
*Goldmacher VS, Thilly WG. 1983. Formaldehyde is mutagenic for cultured human cells. Mutat Res 116:417–422.6835255
Goldstein E, Lippert W. 1985. Cellular acid phosphatase activity: correlation of cytochemical and biochemical measurements. Histochem J 17:381–386.2411688
Goodman JI, Trephly TR. 1971. A comparison of rat and human liver formaldehyde dehydrogenase. Biochim Biophys Acta 252:489–505.4332837
Gordon T, Harkema JR. 1995. Mucous cell metaplasia in the airways of rats exposed to machining fluids. Fundam Appl Toxicol 28:274–282.8835237
Goris JA, Ang S, Navarro C. 1998. Minimizing the toxic effects of formaldehyde. Lab Med 29:39–42.
*Gorski P, Tarkowski M, Krakowiak A, 1992. Neutrophil chemiluminescence following exposure to formaldehyde in healthy subjects and in patients with contact dermatitis. Allergol Immunopathol (Madr) 20:20–23.1387286
*Gossel TA, Bricker JD. 1994. Principles of clinical toxicology. 3rd ed. New York, NY: Raven Press.
*Gottschling LM, Beaulieu HJ, Melvin WW. 1984. Monitoring of formic acid in urine of humans exposed to low levels of formaldehyde. Am Ind Hyg Assoc J 45:19–23.6702592
Grabinska-Loniewska A. 1974. Studies on the activated sludge bacteria participating in the biodegradation of methanol, formaldehyde and ethylene glycol: Part II. Utilization of various carbon and nitrogen compounds. Acta Microbiol Pol Ser B 6:83–88.4209889
Graedel TE, McGill R. 1986. Degradation of materials in the atmosphere: Common materials are vulnerable to atmospheric attack. Environ Sci Technol 20:1093–1100.
*Grafstrom RC, Fornace AJ, Autrup H, 1983. Formaldehyde damage to DNA and inhibition of DNA repair in human bronchial cells. Science 220:216–218.6828890
*Grafstrom RC, Curren RD, Yang LL, 1985. Genotoxicity of formaldehyde in cultured human bronchial fibroblasts. Science 228:89–91.3975633
*Grafstrom RC, Fornace A, Harris CC. 1984. Repair of DNA damage caused by formaldehyde in human cells. Cancer Res 44:4323–4327.6467194
*Graftstrom RC, Hsu I-C, Harris CC. 1993. Mutagenicity of formaldehyde in Chinese hamster lung fibroblasts: Synergy with ionizing radiation and n-nitroso-n-methylurea. Chem Biol Interact 86:41–49.8431964
*Grammar LC, Harris KE, Shaughnessy MA, 1990. Clinical and immunologic evaluation of 37 workers exposed to gaseous formaldehyde. J Allergy Clin Immunol 86:177–181.2384647
Graves RJ, Trueman P, Jones S, 1996. DNA sequence analysis of methylene chloride-induced HPRT mutations in Chinese hamster ovary cells: Comparison with the mutation spectrum obtained for 1,2-dibromoethane and formaldehyde. Mutagenesis 11:229–233.8671744
*Grazuleviciene R, Dulskiene V, Vencloviene J. 1998. Formaldehyde exposure and low birth weight incidence. J Occup Health 40:61–67.
Green DJ, Kulle TJ. 1986. Generation and measurement of formaldehyde in exposure chambers. Am Ind Hyg Assoc J 47:505–508.
Green DJ, Bascom R, Healey EM, 1989. Acute pulmonary response in healthy, nonsmoking adults to inhalation of formaldehyde and carbon. J Toxicol Environ Health 28:261–275.2585534
*Green DJ, Sauder LR, Kulle TJ, 1987. Acute response to 3.0 ppm formaldehyde in exercising health nonsmokers and asthmatics. Am Rev Respir Dis 135:1261–1266.3592401
Green MA, Egle JL J. 1983. Effects of intravenous acetaldehyde, acrolein, formaldehyde and propionaldehyde on arterial blood pressure following acute guanethidine treatment. Res Commun Chem Pathol Pharmacol 40:337–340.6878872
Greenberg SR. 1982. Nucleic acid relationships in formalin-injured renal tubules. Proc Inst Med Chicago 35:83–84.6183658
*Grosjean D. 1982. Formaldehyde and other carbonyls in Los Angeles ambient air. Environ Sci Technol 16:254–262.22257249
*Grosjean D, Wright B. 1983. Carbonyls in urban fog, ice fog, cloudwater and rainwater. Atmos Environ 17:2093–2096.
*Grosjean D, Swanson RD, Ellis C. 1983. Carbonyls in Los Angeles air: Contribution of direct emissions and photochemistry. Sci Total Environ 29:65–85.
*Grosjean E, Grosjean D, Fraser MP, 1996. Air quality model evaluation data for organics. 2. C_1_-C_14_ carbonyls in Los Angeles air. Environ Sci Technol 30:2687–2703.
*Grosjean E, Williams ELII, Grosjean D. 1993. Ambient levels of formaldehyde and acetaldehyde in Atlanta, Georgia. J Air Waste Manage Assoc 43:469–474.
Gross AF, Given PS J, Athnasios AK. 1987. Food. Anal Chem 59:212R–252R.
Gross EA, Morgan KT. 1991. Architecture of nasal passages and larynx. In: Parent RA, ed. Comparative biology of the normal lung. Boca Raton, FL: CRC Press, 7–25.
Groten JP, Schoen ED, Van Bladeren PJ, 1997. Subacute toxicity of a mixture of nine chemicals in rats: Detecting interactive effects with a fractionated two-level factorial design. Fundam Appl Toxicol 36:15–29.9073463
Gryllaki-Berger M, Mugny C, Perrenoud D, 1992. A comparative study of formaldehyde detection using chromotropic acid, acetylacetone and HPLC in cosmetics and household cleaning products. Contact Dermatitis 26:149–154.1505179
Guengerich FP. 1995. Influence of nutrients and other dietary materials on cytochrome P-450 enzymes. Am J Clin Nutr 61(suppl):651S–658S.7879733
Guicherit R, Schulting FL. 1985. The occurrence of organic chemicals in the atmosphere of the Netherlands. Sci Total Environ 43:193–219.4012295
Guillot JP, Gonnet JF. 1985. The epicutaneous maximization test. Curr Probl Dermatol 14:220–247.4064747
Guseva VA. 1972. [Gonadotropic effect of formaldehyde on male rats during its simultaneous induction with air and water]. Gig Sanit 10:102–103. (Russian)
Gustavsson P, Jakobsson R, Johansson H, 1998. Occupational exposures and squamous cell carcinoma of the oral cavity, pharynx, larynx, and oesophagus: a case-control study in Sweden. Occup Environ Med 55:393–400.9764099
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and Differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad LM and Winchester JF. 1990. Clinical Management of Poisoning and Drug Overdose (2nd edition). Philadelphia, PA: WB Saunders.
Haggard HW, Greenberg LA. 1939. Studies in the absorption, distribution and elimination of alcohol. IV. The elimination of methyl alcohol. J Pharmacol Exp Ther 66:479–496.
Hagmar L, Bellander T, Englander V, 1986. Mortality and cancer morbidity among workers in a chemical factory. Scand J Work Environ Health 12:545–551.3823803
Hagmar L, Bellander T, Hogstedt B, 1988a. Biological effects in a chemical factory with mutagenic exposure: I. Cytogenic and haematological parameters. Int Arch Occup Environ Health 60:437–444.3410554
Hagmar L, Bellander T, Persson L, 1988b. Biological effects in a chemical factory with mutagenic exposure: III. Urinary mutagenicity and thioether excretion. Int Arch Occup Environ Health 60:453–456.3410555
Hagmar L, Nielsen J, Skerfving S. 1987. Clinical features and epidemiology of occupational obstructive respiratory disease caused by small molecular weight organic chemicals. In: Schlumberger HD, ed. Epidemiology of allergic diseases. Basel: Karger, 42–58.
*Hall A, Harrington JM, Aw T-C. 1991. Mortality study of British pathologists. Am J Ind Med 20:83–89.1867220
Hallier E, Schroder KR, Asmuth K, 1994. Metabolism of dichloromethane (methylene chloride) to formaldehyde in human erythrocytes: influence of polymorphism of glutathione transferase theta (GST T1–1). Arch Toxicol 68:423–427.7979958
Halperin WE, Goodman M, Stayner L, 1983. Nasal cancer in a worker exposed to formaldehyde. JAMA,J Am Med Assoc 249:510–512.
Hansen ES. 1991. Cancer mortality among Danish molders. Am J Ind Med 20:401–409.1928115
*Hansen J, Olsen JH. 1995. Formaldehyde and cancer morbidity among male employees in Denmark. Cancer Causes Control 6:354–360.7548723
Hansen J, Olsen JH. 1996. [Occupational exposure to formaldehyde and risk of cancer.]. Ugeskr Laeg 158:4191–4194. (Danish).8701536
Hansen J, Olsen JH, Larsen AI. 1994. Cancer morbidity among employees in a Danish pharmaceutical plant. Int J Epidemiol 23:891–898.7860168
Hanst PL, Gay BW J. 1977. Photochemical reactions among formaldehyde, chlorine, and nitrogen dioxide in air. Environ Sci Technol 11:1105–1109.
*Hare DA, Groah WJ, Schweer LG, 1996. Evaluating the contribution of UF-bonded building materials to indoor formaldehyde levels in a newly constructed house. Presented at Washington State University 30^th^ Annual Particleboard/Composite Materials Symposium, Pullman, WA.
Hargis KM, Tillery MI, Ettinger HJ, 1986. Industrial hygiene study of a true in situ oil shale retorting facility. Am Ind Hyg Assoc J 47:455–464.
Harley RA, Cass GR. 1994. Modeling the concentrations of gas-phase toxic organic air pollutants: Direct emissions and atmospheric formation. Environ Sci Technol 28:88–98.22175837
Harman AE, Voigt JM, Frame SR, 1997. Mitogenic responses of rat nasal epithelium to hexamethylphosphoramide inhalation exposure. Mutat Res 380:155–165.9385396
*Harrington JM, Oakes D. 1984. Mortality study of British pathologists: 1974–1980. Br J Ind Med 41:188–191.6722045
*Harrington JM, Shannon HS. 1975. Mortality study of pathologists and medical laboratory technicians. Br Med J 4:329–332.1192055
Harris C, Kenneway M, Lee E, 1995. Formaldehyde embryotoxicity in mouse conceptuses grown in whole embryo culture [Abstract]. Toxicologist 1:162.
Harris DK. 1953. Health problems in the manufacture and use of plastics. Br J Ind Med 10:255–268.13106232
*Harving H, Korsgaard J, Dahl R, 1986. Low concentrations of formaldehyde in bronchial asthma: a study of exposure under controlled conditions. Br Med J 293:310.3089500
*Harving H, Korsgaard J, Pedersen OF, 1990. Pulmonary function and bronchial reactivity in asthmatics during low-level formaldehyde exposure. Lung 168:15–21.2105409
Hasegawa T, Tsuji M, Nakayama S, 1993. [Effects of disinfectants on erythrocytes and isolated hepatocytes from rats and surface tension]. Folia Pharmacol Jpn 101:337–347. (Japanese)
Haselkorn R, Doty P. 1961. The reaction of formaldehyde with polynucleotides. J Biol Chem 236:2738–2745.13905167
Hasselman A, Kolmael KF. 1995. [Occupational dermatoses of cleaning staff]. Arbeitsmed Sozialmed Umweltmed 30:106–120. (German)
Hastie AT. 1986. Inhibition of mammalian ciliary activity by formaldehyde [Abstract]. Am Rev Respir Dis 133:A–84.
Hastie AT, Patrick H, Fish JE. 1990. Inhibition and recovery of mammalian respiratory ciliary function after formaldehyde exposure. Toxicol Appl Pharmacol 102:282–291.2137268
*Hatch GG, Conklin PM, Christensen CC, 1983. Synergism in the transformation of hamster embryo cells treated with formaldehyde and adenovirus. Environ Mutagen 5:49–57.6832085
Hatch KL, Maibach HI. 1986. Textile chemical finish dermatitis. Contact Dermatitis 14:1–13.3512163
Hatch KL, Maibach HI. 1995. Textile dermatitis: an update. (I). Resins, additives and fibers. Contact Dermatitis 32:319–326.7554877
*Hatfield R. 1957. Biological oxidation of some organic compounds. Ind Eng Chem 49:192–196.
*Haworth S, Lawlor T, Mortelmans K, 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl. 1):3–142.
*Hawthorne AR, Dudney CS, Cohen MA, 1986a. Multipollutant indoor air quality study of 300 homes in Kingston/Barriman, Tennessee: Study design [Abstract]. Abstr Pap Am Chem Soc 192:ENVR 96.
*Hawthorne AR, Gammage RB, Dudney CS. 1986b. An indoor air quality study of 40 east Tennessee homes. Environ Int 12:221–239.
*Hayashi T, Reece CA, Shibamoto T. 1986. Gas chromatographic determination of formaldehyde in coffee via thiazolidine derivative. J Assoc Off Anal Chem 69:101–105.3949681
*Hayes RB, Blair A, Stewart PA, 1990. Mortality of U.S. embalmers and funeral directors. Am J Ind Med 18:641–652.2264563
Hayes RB, Klein S, Suruda A, 1997. O6-alkylguanine DNA alkyltransferase activity in student embalmers. Am J Ind Med 31:361–365.9055960
*Hayes RB, Raatgever JW, De Bruyn A, 1986. Cancer of the nasal cavity and paranasal sinuses, and formaldehyde exposure. Int J Cancer 37:487–492.3957459
*HazDat. 1996. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
He JL, Jin LF, Jin HY. 1998. Detection of cytogenic effects in peripheral lymphocytes of students exposed to formaldehyde with cytokinesis-blocked micronucleus assay. Biomed Environ Sci 11:87–92.9559107
Healey EM, Bascom R, Sauder L, 1987. Acute pulmonary response in healthy non-smoking adults to inhalation of carbon and formaldehyde [Abstract]. Am Rev Respir Dis 135:A58.
Hecht SS. 1984. Chemical carcinogenesis: An overview. Clin Physiol Biochem 3:89–97.
*Heck Hd'A, Casanova M. 1987. Isotope effects and their implications for the covalent binding of inhaled [^3^H]- and [^14^C]formaldehyde in the rat nasal mucosa. Toxicol Appl Pharmacol 89:122–134.3590184
*Heck Hd'A, Casanova M. 1994. Nasal dosimetry of formaldehyde: Modeling site specificity and the effects of preexposure. Inhal Toxicol 6:159–175.
Heck Hd'A, Casanova-Schmitz M. 1983. Biochemical toxicology of formaldehyde. In: Hodgson, Bend, Philpot, ed. Reviews in biochemical toxicology. New York, NY: Elsevier, 155–189.
Heck Hd'A, Keller DA. 1988. Toxicology of formaldehyde. ISI Atlas Sci Pharmacol 2:5–9.
Heck Hd'A, Casanova M, McNulty MJ, 1986. Mechanisms of nasal toxicity induced by formaldehyde and acrolein. In: Barrow CS, ed. Toxicology of the nasal passages. Washington, DC: Hemisphere Publishing Corporation, 235–247.
*Heck Hd'A, Casanova M, Starr TB. 1990. Formaldehyde toxicity - new understanding. CRC Crit Rev Toxicol 20:397–426.
*Heck Hd’A, Casanova M, Steinhagen WH 1989. DNA-protein cross-linking studies in rats and nonhuman primates. In: Feron VJ and Bosland MC, eds. Nasal carcinogenesis in rodents: Relevance to human health risk. The Netherlands: Pudoc Wageningen, 159–164. (Cited in EPA, 1991a)
*Heck Hd'A, Casanova-Schmitz M, Dodd PB, 1985. Formaldehyde (CH_2_O) concentrations in the blood of humans and Fischer-344 rats exposed to CH_2_O under controlled conditions. Am Ind Hyg Assoc J 46:1–3.4025145
*Heck Hd'A, Chin TY, Schmitz MC. 1983. Distribution of [^14^C] formaldehyde in rats after inhalation exposure. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 26–37.
*Heck Hd'A, White EL, Casanova-Schmitz M. 1982. Determination of formaldehyde in biological tissues by gas chromatography/mass spectrometry. Biomed Mass Spectrom 9:347–353.7126766
Hedge A, Erickson WA, Rubin G. 1994. The effects of alternative smoking policies on indoor air quality in 27 office buildings. Ann Occup Hyg 38:265–278.8048788
Heinzow B, Elltorr T. 1992. [Formic acid in urine: An useful indicator in environmental medicine?]. Zentralbl Hyg Umweltmed 192:455–461. (German)1554404
Helander I. 1977. Contact urticaria from leather containing formaldehyde. Arch Dermatol 113:1443.562136
Helander KG. 1994. Kinetic studies of formaldehyde binding in tissue. Biotechnic Histochem 69:177–179.
Hellawell JM. 1988. Toxic substances in rivers and streams. Environ Pollut 50:61–85.15092653
*Helrich K. 1990. 964.1 Formaldehyde in maple sirup: Spectrophotometric method. In: Helrich K, ed. Official methods of analysis of the Association of Official Analytical Chemists. Arlington, VA: Association of Official Analytical Chemists, Inc., 1037–1038.
Hemminki K. 1984. Urinary excretion products of formaldehyde in the rat. Chem Biol Interact 48:243–248.6697422
Hemminki K, Kyyronen P, Lindbohm M-L. 1985. Spontaneous abortions and malformations in the offspring of nurses exposed to anaesthetic gases, cytostatic drugs, and other potential hazards in hospitals, based on registered information of outcome. J Epidemiol Commun Health 39:141–147.
*Hendrick DJ, Lane DJ. 1975. Formalin asthma in hospital staff. Br Med J 1:607–608.1125625
*Hendrick DJ, Lane DJ. 1977. Occupational formalin asthma. Br J Ind Med 34:11–18.557329
*Hendrick DJ, Rando RJ, Lane DJ, 1982. Formaldehyde asthma: Challenge exposure levels and fate after five years. J Occup Med 24:893–897.7175584
Herbert FA, Hessel PA, Melenka LS, 1994. Respiratory consequences of exposure to wood dust and formaldehyde of workers manufacturing oriented strand board. Arch Environ Health 49:465–470.7818289
Herbert FA, Hessel PA, Melenka LS, 1995. Pulmonary effects of simultaneous exposures to MDI formaldehyde and wood dust on workers in an oriented strand board plant. J Occup Environ Med 37:461–465.7670902
*Hernberg S, Collan Y, Degerth R, 1983a. Nasal cancer and occupational exposures: Preliminary report of a joint Nordic case-referent study. Scand J Work Environ Health 9:208–213.6648420
*Hernberg S, Westerholm P, Schultz-Larsen K, 1983b. Nasal and sinonasal cancer: Connection with occupational exposures in Denmark, Finland and Sweden. Scand J Work Environ Health 9:315–326.6635610
Herrera JM, Nieves AJ, Gutierrez MD P, 1997. [Citotoxicity produced by formaldehyde (atmospheric contaminant) in the rat central nervous system]. Rev Mex Cienc Farm 28:21–27. (Spanish).
Hess SM, Fitzhugh OG. 1955. Absorption and excretion of certain triphenyl-methane colors in rats and dogs. J Pharmacol Exp Ther 114:38–42.14392569
*Heukelekian H, Rand MC. 1955. Biochemical oxygen demand of pure organic compounds. Sewage Ind Waste 27:1040–1053.
Hileman B. 1983. Indoor air pollution. Environ Sci Technol 17:469A–472A.
*Hilton J, Dearman RJ, Basketter DA, 1996. Experimental assessment of the sensitizing properties of formaldehyde. Food Chem Toxicol 34:571–578.8690318
Hilton J, Dearman RJ, Harvey P, 1998. Estimation of relative skin sensitizing potency using the local lymph node assay: A comparison of formaldehyde with glutaraldehyde. Contact Dermatitis 9:29–33.
*Ho MH, Richards RA. 1990. Enzymatic method for the determination of formaldehyde. Environ Sci Technol 24:201–204.
*Hodgson AT, Wooley JD, Daisey JM. 1993. Emissions of volatile organic compounds from new carpet measured in a large scale environmental chamber. J Air Waste Manage Assoc 43:316–324.
Hogue CJ, Brewster MA. 1991. The potential of exposure biomarkers in epidemiologic studies of reproductive health. Environ Health Perspect 90:261–269.2050070
Holcatova I, Bencko V. 1997. Health aspects of formaldehyde in the indoor environment. Czech and Slovak experience. Cent Eur J Public Health 5:38–42.9151006
Holly EA, Aston DA, Ahn DK, 1996. Intraocular melanoma linked to occupations and chemical exposures. Epidemiology 7:55–61.8664402
Holmstrom M, Lund VJ. 1991. Malignant melanomas of the nasal cavity after occupational exposure to formaldehyde. Br J Ind Med 48:9–11.1993163
Holmstrom M, Wihelmsson B. 1988. Respiratory symptoms and pathophysiological effects of occupational exposure to formaldehyde and wood dust. Scand J Work Environ Health 14:306–311.3201190
*Holmstrom M, Rynnel-Dagoo B, Wilhelmsson B. 1989b. Antibody production in rats after long-term exposure to formaldehyde. Toxicol Appl Pharmacol 100:328–333.2789442
Holmstrom M, Wilhelmsson B, Hellquist H. 1989a. Histological changes in the nasal mucosa in rats after long-term exposure to formaldehyde and wood dust. Acta Otolaryngol (Stockh) 108:274–283.2816342
*Holmstrom M, Wilhelmsson B, Hellquist H, 1989c. Histological changes in the nasal mucosa in persons occupationally exposed to formaldehyde alone and in combination with wood dust. Acta Otolaryngol (Stockh) 107:120–129.2929309
*Holness DL, Nethercott JR. 1989. Health status of funeral service workers exposed to formaldehyde. Arch Environ Health 44:222–228.2528945
Homma Y, Oyasu R. 1986. Transient and persistent hyperplasia in heterotopically transplanted rat urinary bladders induced by formalin and foreign bodies. J Urol 136:136–140.3712600
Homma Y, Nowels K, Oyasu R. 1986. Effects of formalin-induced injuries on urinary bladder carcinogenesis. Cancer Lett 32:17–23.
*Hoogenboom BE, Hynes RW, Mann CM, 1987. Validation of a colorimetric method for determination of atmospheric formaldehyde. Am Ind Hyg Assoc J 48:420–424.3591661
Hoover MD, Harkema JR, Muggenburg BA, 1993. A microspray nozzle for local administration of liquids or suspensions to lung airways via bronchoscopy. J Aerosol Med 6:67–72.10146276
Hopkins J. 1985. Formaldehyde epidemiology: A mouthful of uncertainty. Food Chem Toxicol 23:1024–1028.
Horsfall FL J. 1934. Formaldehyde hypersensitiveness. An experimental study. J Immunol 27:569–581.
Horton V L, Higuchi MA, Rickert DE. 1992. Physiologically based pharmacokinetic model for methanol in rats, monkeys, and humans. Toxicol Appl Pharmacol 117:26–36.1440610
*Horvath EP, Anderson H, Pierce WE, 1988. Effects of formaldehyde on the mucous membranes and lungs: A study of an industrial population. JAMA,J Am Med Assoc 259:701–707.
*Hose JE, Lightner DV. 1980. Absence of formaldehyde residues in Penaeid shrimp exposed to formalin. Aquaculture 21:197–201.
*Howard PH. 1989. Formaldehyde. In: Howard PH, ed. Handbook of Environmental Fate and Exposure Data for Organic Chemicals. Chelsea, MI: Lewis Publishers, 342–350.
Howick CJ, McCarthy SA. 1996. Studies of possible chemical emissions from PVC articles used in indoor applications and the effect on indoor air quality. J Vinyl Addit Technol 2:134–142.
Howlett CT, Mathias R, Friess S. 1989. Quantitative risk approaches for formaldehyde. Exp Pathol 37:119–127.2700168
Hoxey EV, Soper CJ, Davies DJ G. 1985. Biological indicators for low temperature steam formaldehyde sterilization: Effect of defined media on sporulation, germination index and moist heat resistance at 110 degrees C of bacillus strains. J Appl Bacteriol 58:207–214.3980302
*HSDB. 1999. Hazardous Substance Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda MD. March 3, 1999.
Hubal EA C, Schlosser PM, Conolly RB, 1997. Comparison of inhaled formaldehyde dosimetry predictions with DNA-protein cross-link measurements in the rat nasal passages. Toxicol Appl Pharmacol 143:47–55.9073591
*Hurni H, Ohder H. 1973. Reproduction study with formaldehyde and hexamethylenetetramine in beagle dogs. Food Cosmet Toxicol 11:459–462.4728231
*Hushon J, Clerman R, Small R, 1980. An assessment of potentially carcinogenic energy-related contaminants in water. McLean, VA: Prepared for US Department of Energy and National Cancer Institute.
Ianysheva NI, Balenko NV, Chernichenko IA, 1998. [Characteristics of modifying effects of formaldehyde on carcinogenesis]. Gig Sanit 1:51–54. (Russian) [Translation in progress].
*IARC. 1982. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Vol. 29: Some industrial chemicals and dyestuffs. World Health Organization, Lyon, France.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Supp. 7: Overall evaluations of carcinogenicity: An updating of volumes 1 to 42. World Health Organization, Lyon, France.
*IARC. 1995. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Vol. 62: Wood dusts and formaldehyde. World Health Organization, Lyon, France.
*Igawa M, Munger WJ, Hoffman MR. 1989. Analysis of aldehydes in cloud- and fogwater samples by HPLC with a postcolumn reaction detector. Environ Sci Technol 23:556–561.
Imbus HR. 1985. Clinical evaluation of patients with complaints related to formaldehyde exposure. J Allergy Clin Immunol 76:831–840.3905920
Imbus HR. 1988. A review of regulatory risk assessment with formaldehyde as an example. Regul Toxicol Pharmacol 8:356–366.3070647
Infante PF, Schneiderman MA. 1986. Formaldehyde, lung cancer and bronchitis. Lancet 1:436–437.
Infante PF, Ulsamer AG, Groth D, 1981. Health hazards of formaldehyde. Lancet Oct. 31:980–982.
Inour T, Ishiwata H, Yoshirhira K. 1987. Chemical, physical and microbiological indexes to the surface deterioration of melamine resin. J Food Hyg Soc Jpn 28:348–353.
International Expert Panel on Carcinogen Risk Assessment. 1996. The use of mechanistic data in the risk assessments of ten chemicals: An introduction to the chemical-specific reviews. Pharmacol Ther 71:1–5.8910946
IRIS. 1995. Integrated Risk Information System (IRIS). Online. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, Cincinnati, OH. October 1995.
IRIS. 1998. Integrated Risk Information System (IRIS). Online. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, Cincinnati, OH. November 1998. http://www.epa.gov/ngispgm3/iris/subst.
*IRIS. 1999. Integrated Risk Information System (IRIS). Online. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, Cincinnati, OH. April 1999. http://www.epa.gov/ngispgm3/iris/subst.
*IRPTC. 1985. Treatment and disposal methods for waste chemicals. International Registry of Potentially Toxic Chemicals. United Nations Environmental Programme, Geneva, Switzerland.
Ito K, Sakamoto T, Hayashi Y, 1996. Role of tachykinin and bradykinin receptors and mast cells in gaseous formaldehyde-induced airway microvascular leakage in rats. Eur J Pharmacol 307:291–298.8836617
*Iversen OH. 1986. Formaldehyde and skin carcinogenesis. Environ Int 12:541–544.
*Iversen OH. 1988. Formaldehyde and skin tumorigenesis in Sencar mice. Environ Int 14:23–28.
*Jankovic J, Jones W, Burkhart J, 1991. Environmental study of firefighters. Ann Occup Hyg 35:581–602.1768008
Jarvholm B, Ljungkivst G, Laventius B, 1995. Acetic aldehyde and formaldehyde in cutting fluids and their relation to irritant symptoms. Ann Occup Hyg 39:591–601.8526393
*Jeffcoat AR, Chasalow F, Feldman DB. 1983. Disposition of [^14^C] formaldehyde after topical exposure to rats, guinea pigs, and monkeys. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 38–50.
Jeng H-W, Feigal RJ, Messer HH. 1987. Comparison of the cytotoxicity of formocresol, formaldehyde, cresol, and glutaraldehyde using human pulp fibroblast cultures. Pediatr Dent 9:295–300.3148905
*Jensen OM, Andersen SK. 1982. Lung cancer risk from formaldehyde. Lancet 1:913.
Ji C, Mirvish SS, Nickols J, 1989. Formation of hydroxy derivative, aldehydes, and nitrite from n-nitrosomethyl-n-amylamine by rat liver microsomes and by purified cytochrome P-450 IIB1. Cancer Res 49:5299–5304.2766298
Jiang X-zhi Zhang R-wen. 1988. The toxicity and potential risk of occupational exposure to formaldehyde. In: Xue S-Z, Liang Y-X, ed. Occupational health in industrialization and modernization. Shanghai: Shanghai Medical University Press, 70–74.
*Johannsen FR, Levinskas GJ, Tegeris AS. 1986. Effects of formaldehyde in the rat and dog following oral exposure. Toxicol Lett 30:1–6.3952767
*Johanson CE. 1980. Permeability and vascularity of the developing brain: cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johansson EB, Tjalve H. 1978. The distribution of [^14^C] dimethylnitrosamine in mice. Autoradiographic studies in mice with inhibited and noninhibited dimethylnitrosamine metabolism and a comparison with the distribution of [^14^C]formaldehyde. Toxicol Appl Pharmacol 45:565–575.568326
John EM, Savitz DA, Shy CM. 1994. Spontaneous abortions among cosmetologists. Epidemiology 5:147–155.8172989
Jones AW. 1987. Elimination half-life of methanol during hangover. Pharmacol Toxicol 60:217–220.3588516
Kalabokas P, Carlier P, Fresnet P, 1988. Field studies of aldehyde chemistry in the Paris area. Atmos Environ 22:147–155.
*Kamata E. 1966. Aldehydes in lake and sea waters. Bull Chem Soc Jpn 39:1227–1229.
*Kamata E, Nakadate M, Uchida O, 1996a. Effects of formaldehyde vapor on the nasal cavity and lungs of F-344 rats. J Environ Pathol Toxicol Oncol 15:1–8.9037259
*Kamata E, Nakadate M, Ogawa Y, 1996b. Acute inhalation toxicity study of formaldehyde in rats: Effect of vapor on the pulmonary surfactant. Pharmacometrics 51:33–37.
*Kamata E, Nakadate M, Uchida O, 1997. Results of a 28-month chronic inhalation toxicity study of formaldehyde in male Fischer-344 rats. J Toxicol Sci 22:239–254.
Kamata E, Uchida O, Suzuki S, 1984. Toxicological effects of some inhaled chemicals on the respiratory tract and the lungs of rats (first report) [Abstract]. Toxicol Sci 9:303.
Kamata E, Uchida O, Suzuki S, 1985. Toxicological effects of some inhaled chemicals on the respiratory tract and the lungs of rats (2nd report) [Abstract]. Toxicol Sci 10:258.
Kaminski J, Atwal AS, Mahadevan S. 1993a. High performance liquid chromatographic determination of formaldehyde in milk. J Liquid Chromatogr 16:521–526.
*Kaminski J, Atwal AS, Mahadevan S. 1993b. Determination of formaldehyde in fresh and retail milk by liquid column chromatography. J Assoc Off Anal Chem 76:1010–1013.
*Kane LE, Alarie Y. 1977. Sensory irritation to formaldehyde and acrolein during single and repeated exposures in mice. Am Ind Hyg Assoc J 38:509–522.562615
Kang KM, Corey G, Storrs FJ. 1995. Follow-up study of patients allergic to formaldehyde and formaldehyde releasers: Retention of information, compliance, course, and persistence of allergy. Contact Dermatitis 6:209–215.
*Kao AS. 1994. Formation and removal reactions of hazardous air pollutants. J Air Waste Manage Assoc 44:683–696.
*Karlberg A-T, Skare L, Lindberg I, 1998. A method for quantification of formaldehyde in the presence of formaldehyde donors in skin-care products. Contact Dermatitis 38:20–28.9504242
Katakura Y, Kishi R, Okui T, 1993. Distribution of radioactivity from 14C-formaldehyde in pregnant mice and their fetuses. Br J Ind Med 50:176–182.8435351
Katayama N, Honda Y, Fujimaki H. 1992. Growth and functional modifications in formaldehyde-treated mouse bone marrow-derived mast cells. Toxicol in Vitro 6:239–243.20732119
Keefer LK, Streeter AJ, Leung LY, 1987. Pharmacokinetic and deuterium isotope effect studies on the metabolism of formaldehyde and formate to carbon dioxide in rats in vivo. Drug Metab Dispos 15:300–304.2886303
Keller DA, Heck Hd'A, Randall HW, 1990. Histochemical localization of formaldehyde dehydrogenase in the rat. Toxicol Appl Pharmacol 106:311–326.2256119
*Kelly TJ, Mukund R, Spicer CW, 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28:378A–387A.
*Kelly TJ, Satola JR, Smith DL. 1996. Emission Rates of Formaldehyde and Other Carbonyls from Consumer and Industrial Products Found in California Homes. In: Meas. Toxic Relat. Air Pollut., Proc. Int. Spec. Conf. Pittsburgh, PA: Air & Waste Management Association, 521–526.
Kennedy G, Slaich PK, Golding BT, 1996. Structure and mechanism of formation of a new adduct from formaldehyde and guanosine. Chem Biol Interact 102:93–100.8950224
*Kepler GM, Joyner DR, Fleishman A, 1995. Method for obtaining accurate geometrical coordinates of nasal airways for computer dosimetry modeling and lesion mapping. Inhal Toxicol 7:1207–1224.
*Kepler GM, Richardson RB, Morgan KT, 1998. Computer simulation of inspiratory nasal airflow and inhaled gas uptake in a Rhesus monkey. Toxicol Appl Pharmacol 150:1–11.9630447
Kerns WD, Donofrio DJ, Pavkov KL. 1983a. The chronic effects of formaldehyde inhalation in rats and mice: A preliminary report. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 111–131.
*Kerns WD, Pavkov KL, Donofrio DJ, 1983b. Carcinogenicity of formaldehyde in rats and mice after long-term inhalation exposure. Cancer Res 43:4382–4391.6871871
*Khamgaonkar MB, Fulare MB. 1991. Pulmonary effects of formaldehyde exposure - an environmental-epidemiological study. Indian J Chest Dis Allied Sci 33:9–13.1791022
Khamgaonkar MB, Fulare MB. 1992. Formaldehyde induced symptoms in medical laboratories. Indian J Ind Med 38:129–131.
Kiec-Swierczynska M. 1995. [Preliminary assessment of the effect of disinfectants on skin changes in health service workers.]. Med Pr 46:149–150. (Polish)7637633
*Kiec-Swierczynska M. 1996. Occupational allergic contact dermatitis in Lodz: 1990–1994. Occup Med 48:205–208.
*Kiefer M, Moss CE. 1997. Laser generated air contaminants released during laser cutting of fabrics and polymers. J Laser Appl 9:7–13.
*Kilburn KH. 1994. Neurobehavioral impairment and seizures from formaldehyde. Arch Environ Health 49:37–44.8117145
Kilburn KH, Moro A. 1985. Reproductive and maternal effects of formaldehyde (HCHO) in rats [Abstract]. Fed Proc 44:535.
*Kilburn KH, Warshaw RH. 1992. Neurobehavioral effects of formaldehyde and solvents on histology technicians: Repeated testing across time. Environ Res 58:134–146.1511669
*Kilburn KH, Warshaw R, Boylen CT, 1985a. Pulmonary and neurobehavioral effects of formaldehyde exposure. Arch Environ Health 40:254–260.4062359
*Kilburn KH, Seidman BC, Warshaw BA. 1985b. Neurobehavioral and respiratory symptoms of formaldehyde and xylene exposure in histology technicians. Arch Environ Health 40:229–233.4051579
*Kilburn KH, Warshaw R, Thornton JC. 1987. Formaldehyde impairs memory, equilibrium and dexterity in histology technicians: Effects which persist for days after exposure. Arch Environ Health 42:117–120.3579365
Kilburn KH, Warshaw R, Thornton JC. 1989. Pulmonary function in histology technicians compared with women from Michigan: effects of chronic low dose formaldehyde on a national sample of women. Br J Ind Med 46:468–472.2765419
*Kimbell JS, Gross EA, Joyner DR, 1993. Application of computational fluid dynamics to regional dosimetry of inhaled chemicals in the upper respiratory tract of the rat. Toxicol Appl Pharmacol 121:253–263.8346542
*Kimbell JS, Gross EA, Richardson RB, 1997a. Correlation of regional formaldehyde flux predictions with the distribution of formaldehyde-induced squamous metaplasia in F344 rat nasal passages. Mutat Res 380:143–154.9385395
*Kimbell JS, Subramaniam RP, Miller FJ. 1997b. Computer models of nasal airflow inhaled gas uptake in the rat, monkey, and human: Implications for interspecies dosimetry. CIIT Act 17:1–12.
King JL, Rappaport SM. 1992. Application of an anova model to evaluate occupational exposure to formaldehyde [Abstract]. Am Chem Soc Abstr Pap 203rd ACS National Meeting:CHAS 37.
*Kirchstetter TW, Singer BC, Harley RA, 1996. Impact of oxygenated gasoline use on California light-duty vehicle emissions. Environ Sci Technol 30:661–670.
*Kirschner EM. 1996. Growth of top 50 chemicals slowed in 1995 from very high 1994 rate. Chem Eng News 74:16–18.
Kitaeva LV, Mikheeva EA, Shelomova LF, 1996. [Genotoxic effect of formaldehyde in somatic human cells in vivo]. Genetika 32:1287–1290. (Russian) [Translation in progress]9026467
*Klaassen CD. 1996. Air pollution. In: Klaassen CD, Amdur MO, Doull J, ed. Casarett and Doull's Toxicology: the basic science of poisons. New York: McGraw-Hill, 877–878.
Kleindienst TE, Hudgens EE, Smith DF, 1993. Comparison of chemiluminescence and ultraviolet ozone monitor responses in the presence of humidity and photochemical pollutants. J Air Waste Manage Assoc 43:213–222.
*Kleindienst TE, Shepson PB, Edney EO, 1986. Wood smoke: Measurement of the mutagenic activities of its gas and particulate-phase photooxidation products. Environ Sci Technol 20:493–501.19994934
Klein-Szanto AJ P, Ura H, Resau J. 1989. Formaldehyde-induced lesions of xenotransplanted human nasal respiratory epithelium. Toxicol Pathol 17:33–37.2749134
*Kligerman AD, Phelps MC, Erexsan GL. 1984. Cytogenetic analysis of lymphocytes from rats following formaldehyde inhalation. Toxicol Lett 21:241–246.6740713
Kline BS. 1925. Formaldehyde poisoning with report of a fatal case. Arch Intern Med 36:220–228.
Koch P. 1995. Occupational contact dermatitis from colophony and formaldehyde in banknote paper. Contact Dermatitis 32:371–372.7554896
*Kochhar R, Nanda V, Nagi B, 1986. Formaldehyde-induced corrosive gastric cicatrization: Case report. Hum Toxicol 5:381–382.3804355
*Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Konopinski VJ. 1983. Formaldehyde in office and commercial environments. Am Ind Hyg Assoc J 44:205–208.6846146
Koo WW K, Kaplan LA, Krug-Wispe SK. 1988. Aluminum contamination of infant formulas. JPEN,J Parenter Enteral Nutr 12:170–173.3361685
*Koppel C, Baudisch H, Schneider V, 1990. Suicidal ingestion of formalin with fatal complications. Intensive Care Med 16:212–214.2351782
*Korky JK, Schwarz SR, Lustigman BK. 1987. Formaldehyde concentrations in biology department teaching facilities. Bull Environ Contam Toxicol 18:907–910.
*Kornbrust DJ, Bus JS. 1983. The role of glutathione and cytochrome P-450 in the metabolism of methyl chloride. Toxicol Appl Pharmacol 67:246–256.6836579
*Korpan YI, Gonchar MV, Starodub NF, 1993. A cell biosensor specific for formaldehyde based on pH-sensitive transistors coupled to methylotrophic yeast cells with genetically adjusted metabolism. Anal Biochem 215:216–222.8122781
*Krakowiak A, Gorski P, Pazdrak K, 1998. Airway response to formaldehyde inhalation in asthmatic subjects with suspected respiratory formaldehyde sensitization. Am J Ind Med 33:274–281.9481426
*Kramps JA, Peltenburg LT C, Kerklaan PR M, 1989. Measurement of specific IgE antibodies in individuals exposed to formaldehyde. Clin Exp Allergy 19:509–514.2790559
Kranke B, Aberer W. 1997. [Severe anaphylactoid reactions to formaldehyde and paraformaldehyde in dentistry]. Allergologie 20:246–251. (German)
Kranke B, Szolar-Platzer C, Aberer W. 1996. Reactions to formaldehyde and formaldehyde releasers in a standard series. Contact Dermatitis 35:192–193.8930496
Kreiger N. 1983. Formaldehyde and nasal cancer mortality. Can Med Assoc J 128:248–249.6821779
*Kreiger RA, Garry VF. 1983. Formaldehyde-induced cytotoxicity and sister-chromatid exchanges in human lymphocyte cultures. Mutat Res 120:51–55.6835262
*Kriebel D, Sama SR, Cocanour B. 1993. Reversible pulmonary responses to formaldehyde: A study of clinical anatomy students. Am Rev Respir Dis 148:1509–1515.8256892
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Anderson ME, Clewell HJIII, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
*Krivanek ND, Imbus HR. 1992. Formaldehyde - studies on irritation at low levels. Comments Toxicol 4:315–330.
Krokan H, Grafstrom RC, Sundqvist K, 1985. Cytotoxicity, thiol depletion and inhibition of O^6^-methylguanine-DNA methyltransferase by various aldehydes in cultured human bronchial fibroblasts. Carcinogenesis 6:1755–1760.4064250
*Krootila K, Uusitalo H, Lehtosalo JI, 1986. Effect of topical chemical irritation on the blood-aqueous barrier of the right eye. Ophthalmic Res 18:248–252.3774290
*Krzyzanowski M, Quackenboss JJ, Lebowitz MD. 1990. Chronic respiratory effects of indoor formaldehyde exposure. Environ Res 52:117–125.2394203
Ku RH, Billings RE. 1986. The role of mitochondrial gluthione and cellular protein sulfhydryls in formaldehyde toxicity in glutathione-depleted rat hepatocytes. Arch Biochem Biophys 247:183–189.3707139
*Kulle TJ. 1993. Acute odor and irritation response in health nonsmokers with formaldehyde exposure. Inhal Toxicol 5:323–332.
Kulle TJ, Green DJ, Sauder LR. 1986. Acute pulmonary effects of 3.0 ppm formaldehyde in exercising healthy nonsmokers and asthmatics [Abstracts]. Am Rev Respir Dis 133:A 355.
*Kulle TJ, Sauder LR, Hebel JR, 1987. Formaldehyde dose-response in healthy nonsmokers. J Air Pollut Control Assoc 37:919–924.
*Kumar S. 1986. Reactive scavenging of pollutants by rain: A modeling approach. Atmos Environ 20:1015–1024.
Kuo HW, Jian GJ, Liu CS, 1997. White blood cell count as an indicator of formaldehyde exposure. Bull Environ Contam Toxicol 59:261–267.9211697
*Kuykendall JR, Trela BA, Bogdanffy MS. 1995. DNA-protein crosslink formation in rat nasal epithelial cells by hexamethylphosphoramide and its correlation with formaldehyde production. Mutat Res 343:209–218.7623875
Ladanyi E, Stalder K. 1986. Differential pulse-polarographic determination of formaldehyde in lung surfactant. Bioelectrochem Bioenerg 15:89–93.
Lai Y-L. 1991. Comparative ventilation of the normal lung. In: Parent RA, ed. Comparative biology of the normal lung. Boca Raton, FL: CRC Press, 217–239.
*Lam C-W, Casanova M, Heck Hd'A. 1985. Depletion of nasal mucosal glutathione by acrolein and enhancement of formaldehyde-induced DNA-protein cross-linking by simultaneous exposure to acrolein. Arch Toxicol 58:67–71.4091658
*Lamb B, Westberg H, Bryant P, 1985. Air infiltration rates in pre- and post-weatherized houses. J Air Pollut Control Assoc 35:541–551.4008750
Langhorst ML, Coyne LB. 1987. Industrial hygiene. Anal Chem 59:1R–17R.3619040
*Lawryk NJ, Weisel CP. 1996. Concentrations of volatile organic compounds in the passenger compartments of automobiles. Environ Sci Technol 30:810–816.
*Lawryk NJ, Lioy PJ, Weisel CP. 1995. Exposure to volatile organic compounds in the passenger compartment of automobiles during periods of normal and malfunctioning operation. J Expo Anal Environ Epidemiol 5:511–531.8938247
Le L, Ayer S, Place AR, 1990. Analysis of formaldehyde-induced Adh mutations in Drosophila by RNA structure mapping and direct sequencing of PCR-amplified genomic DNA. Biochem Gen 28:367–387.
Lee HK, Alarie Y, Karol MH. 1984. Induction of formaldehyde sensitivity in guinea pigs. Toxicol Appl Pharmacol 75:147–155.6464018
Lee Y-N, Zhou X. 1993. Method for the determination of some soluble atmospheric carbonyl compounds. Environ Sci Technol 27:749–756.
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: implications for practice. Pediatr Clin North Am 44:55–77.9057784
Lehotay J, Hromulakova K. 1994. HPLC determination of trace levels of aliphatic aldehydes C_1_-C_4_ in river and tap water using on-line preconcentration. J Liquid Chromatogr 17:579–588.
Leikauf GD, Doupnik CA. 1989. Formaldehyde-induced bronchial hyperresponsiveness in guinea pig [Abstract]. Am Rev Respir Dis 139:A392.
Leininger JR, Gross EA, Monticello TM, 1995. Morphogenesis of formaldehyde-induced neoplastic nasal lesions in male F344 rats [Abstract]. Proc Am Assoc Cancer Res 36:130.
*Lemiere C, Desjardins A, Cloutier Y, 1995. Occupational asthma due to formaldehyde resin dust with and without reaction to formaldehyde gas. Eur Resp J 8:861–865.
Le Moual N, Orlowski E, Schenker MB, 1995. Occupational exposures estimated by means of job exposure matrices in relation to lung function in the PAARC survey. Occup Environ Med 52:634–643.7489052
*Leonardos G, Kendall D, Barnard N. 1969. Odor threshold determinations of 53 odorant chemicals. J Air Pollut Control Assoc 19:91–95.
*Leovic KW, Sheldon LS, Whitaker DA, 1996. Measurement of indoor air emissions from dry-process photocopy machines. J Air Waste Manage Assoc 46:821–829.
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, ed. General and applied toxicology. New York: Stockton Press, 153–164.
Levin J-O, Lindahl R, Andersson K. 1989. Monitoring of parts-per-billion levels of formaldehyde using a diffuse sampler. J Air Waste Manage Assoc 39:44–47.
*Levine RJ, Andjelkovich DA, Shaw LK. 1984a. The mortality of Ontario undertakers and a review of formaldehyde-related mortality studies. J Occup Med 26:740–746.6491780
Levine RJ, DalCorso D, Blunden PB, 1984b. The effects of occupational exposure on the respiratory health of West Virginia morticians. J Occup Med 26:91–98.6707776
Levison LA. 1904. A case of fatal formaldehyd poisoning. JAMA,J Am Med Assoc 42:1492.
Levy RJ, Schoen FJ, Sherman FS, 1986. Calcification of subcutaneously implanted Type I collagen sponges: Effects of formaldehyde and glutaraldehyde pretreatments. Am J Pathol 122:71–82.3079959
Levy S, Nocentini S, Billardon C. 1983. Induction of cytogenetic effects in human fibroblast cultures after exposure to formaldehyde or X-rays. Mutat Res 119:309–317.6828066
Lewin S. 1966. Reaction of salmon sperm deoxyribonucleic acid with formaldehyde. Arch Biochem Biophys 113:584–602.5949798
Lewis BB, Chestner SB. 1981. Formaldehyde in dentistry: a review of mutagenic and carcinogenic potential. J Am Dent Assoc 103:429–434.7024387
*Lewis RJ. 1993. Hawley's Condensed chemical dictionary. 12^th^ ed. New York, NY: Van Nostrand Reinhold Company.
Li AP, Gupta RS, Heflich RH, 1988. A review and analysis of the Chinese hamster ovary/hypoxanthine-guanine phosphoribosyltransferase assay to determine the mutagenicity of chemical agents. A report of phase III of the U.S. Environmental Protection Agency Gene-Tox Program. Mutat Res 196:17–36.3292898
*Li Q, Wang ZY, Inagaki H, 1995. Evaluation of contact sensitivity to formaldehyde and tetramethylthiuram monosulfide using a modified lymphocyte transformation test. Toxicology 104:17–23.8560496
*Liber HL, Benforado K, Crosby RM, 1989. Formaldehyde-induced and spontaneous alterations in human hprt DNA sequence and mRNA expression. Mutat Res 226:31–37.2716766
*Lide DR, Frederikse HP R. 1996. CRC Handbook of chemistry and physics: A ready-reference book of chemical and physical data. 77th ed. Boca Raton, FL: CRC Press.
Liden S, Scheynius A, Fischer T, 1993. Absence of specific IgE antibodies in allergic contact sensitivity to formaldehyde. Allergy 48:525–529.7902023
Liebling T, Rosenman KD, Pastides H, 1984. Cancer mortality among workers exposed to formaldehyde. Am J Ind Med 5:423–428.6731443
*Liesivuori J, Savolainen H. 1987. Urinary formic acid as an indicator of occupational exposure to formic acid and methanol. Am Ind Hyg Assoc J 48:32–34.3565260
Liesivuori J, Savolainen H. 1991. Methanol and formic acid toxicity: Biochemical mechanisms. Pharmacol Toxicol 69:157–163.1665561
Lin JM, Tang CS. 1994. Characterization and aliphatic aldehyde content of particulates in Chinese incense smoke. Bull Environ Contam Toxicol 53:895–901.7881219
*Lin Y, Duecker SR, Jones AD, 1995. Protocol for collection and HPLC analysis of volatile carbonyl compounds in breath. Clin Chem 41:1028–1032.7600683
Lindskov R. 1982. Contact urticaria to formaldehyde. Contact Dermatitis 8:333–334.6216052
Lipari F, Dasch JM, Scruggs WF. 1984. Aldehyde emissions from wood-burning fireplaces. Environ Sci Technol 18:326–330.22280078
Liu K-S, Petreas M, Hayward S. 1986. A survey of formaldehyde concentrations inside California mobile homes [Abstract]. Prepr Pap Natl Meet Am Chem Soc Div Environ Chem September 7–12, 1986:ENVR 94.
Liu KS, Huang FY, Hayward SB, 1991. Survey of formaldehyde concentrations and health effects in mobile homes [Abstract]. Arch Environ Health 46:181–182.
Loden M. 1986a. The in vitro permeability of human skin to benzene, ethylene glycol, formaldehyde, and n-hexane. Acta Pharmacol Toxicol (Copenh) 58:382–389.3739733
Loden M. 1986b. The effect of 4 barrier creams on the absorption of water, benzene, and formaldehyde into excised human skin. Contact Dermatitis 14:292–296.3743039
*Lofroth G, Burton RM, Forehand L, 1989. Characterization of environmental tobacco smoke. Environ Sci Technol 23:610–614.
*Logue JN, Barrick MK, Jessup GL. 1986. Mortality of radiologists and pathologists in the Radiation Registry of Physicians. J Occup Med 28:91–99.3950788
*Loomis TA. 1979. Formaldehyde toxicity. Arch Pathol Lab Med 103:321–324.110285
Lowe DC, Schmidt U. 1983. Formaldehyde (HCHO) measurements in the nonurban atmosphere. J Geophys Res 88:10844–10858.
*Lowe DC, Schmidt U, Ehhalt DH. 1980. A new technique for measuring tropospheric formaldehyde [CH_2_O]. Geophys Res Lett 7:825–828.
Lowe DC, Schmidt U, Ehhalt DH, 1981. Determination of formaldehyde in clean air. Environ Sci Technol 15:819–823.
Lowengart RA, Peters JM, Cicioni C, 1987. Childhood leukemia and parents' occupational and home exposures. J Natl Cancer Inst 79:39–46.3474448
Luce D, Gerin M, Berrino F, 1993a. Sources of discrepancies between a job exposure matrix and a case by case expert assessment for occupational exposure to formaldehyde and wood-dust. Int J Epidemiol 22:S113–S120.8132384
*Luce D, Gerin M, Leclerc A, 1993b. Sinonasal cancer and occupational exposure to formaldehyde and other substances. Int J Cancer 53:224–231.8425759
*Luker MA, Van Houten RW. 1990. Control of formaldehyde in a garment sewing plant. Am Ind Hyg Assoc J 51:541–544.
Lutz KL. 1986. Endogenous formaldehyde does not produce detectable DNA-protein crosslinks in rat liver. Toxicol Pathol 14:462–465.3809898
*Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Reehl WF, Rosenblatt DH, ed. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York: McGraw-Hill Book Company, 4–1 to 4–33.
Lynen R, Rothe M, Gallasch E. 1983. Characterization of formaldehyde-related antibodies encountered in hemodialysis patients at different stages of immunization. Vox Sang 44:81–89.6402858
Ma T-H, Harris MM. 1985. Genotoxicity studies of formaldehyde using Tradescantia-micronucleus test [Abstract]. Environ Mutagen 7:42.
Ma T-H, Harris MM. 1988. Review of the genotoxicity of formaldehyde. Mutat Res 196:37–59.3292899
Ma T-H, Xu Z, Harris MM, 1986. Dose-response of formaldehyde-fume-induced chromosome damage in tradescantia pollen mother cells [Abstract]. Environ Mutagen 8:49.
MacGregor JT, Tucker JD, Ziderman II, 1989. Non-clastogenicity in mouse bone marrow of fructose/lysine and other sugar/amino acid browning products with in vitro genotoxicity. Food Chem Toxicol 27:715–721.2515134
Mackay DM, Cherry JA. 1989. Groundwater contamination: Pump-and-treat remediation. Environ Sci Technol 23:630–636.
Magnani C, Comba P, Ferraris F, 1993. A case-control study of carcinomas of the nose and paranasal sinuses in the woolen textile manufacturing industry. Arch Environ Health 48:94–97.8476310
Magras IN. 1996. Formaldehyde vapour effects in chicken embryo. Anat Histol Embryol 25:197–200.8976614
*Maibach H. 1983. Formaldehyde: effects on animal and human skin. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 166–174.
Majumder PK, Kumar VL. 1995. Inhibitory effects of formaldehyde on the reproductive system of male rats. Indian J Physiol Pharmacol 39:80–82.7705878
*Malaka T, Kodama AM. 1990. Respiratory health of plywood workers occupationally exposed to formaldehyde. Arch Environ Health 45:288–294.2256713
Malcolm AR, Mills LJ, Trosko JE. 1985. Effects of ethanol, phenol, formaldehyde, and selected metabolites on metabolic cooperation between Chinese hamster V79 lung fibroblasts. Carcinogenesis 8:305–318.
Malek FA, Moritz KU, Bienengraber V, 1997. Influence of formaldehyde on the open field behavior of rats [Abstract]. Teratology 56:399.
*Mansfield CT, Hodge BT, Hege RB, 1977. Analysis of formaldehyde in tobacco smoke by high performance liquid chromatography. J Chromatogr Sci 15:301–302.561117
Manzardo S, Coppi G. 1991. [Protective action of certain compounds against the toxic action of acetaldehyde, acrolein and formaldehyde in the rat]. Boll Chim Farm 130:399–401. (Italian)1805874
Marison IW, Attwood MM. 1982. A possible alternative mechanism for the oxidation of formaldehyde to formate. J Gen Microbiol 128:1441–1446.
*Marks JG J, Belsito DV, DeLeo VA, 1995. North American contact dermatitis group standard tray patch test results (1992 to 1994). Am J Contact Dermatitis 6:160–165.
*Marks TA, Worthy WC, Staples RE. 1980. Influence of formaldehyde and Sonacide (potentiated acid glutaraldehyde) on embryo and fetal development in mice. Teratology 22:51–58.6777891
*Maronpot RR, Miller RA, Clarke WJ, 1986. Toxicity of formaldehyde vapor in B6C3F1 mice exposed for 13 weeks. Toxicology 41:253–266.3775776
Marsh GM. 1982. Proportional mortality patterns among chemical plant workers exposed to formaldehyde. Br J Ind Med 39:313–322.7138792
*Marsh GM, Stone RA, Esmen NA, 1994. Mortality patterns among chemical plant workers exposed to formaldehyde and other substances. J Natl Cancer Inst 86:384–386.8308930
*Marsh GM, Stone RA, Esmen NA, 1996. Mortality among chemical workers in a factory where formaldehyde was used. Occup Environ Med 53:613–627.8882119
Marshall E. 1987. EPA indicts formaldehyde, 7 years later. Science 236:381.3563516
Martin RE, Hizo CB, Ong AM, 1992. Release of formaldehyde and melamine from melamine tableware manufactured in the Philippines. J Food Prot 55:632–635.31071887
*Martin WJ. 1990. A teratology study of inhaled formaldehyde in the rat. Reprod Toxicol 4:237–239.2136043
Marzulli FN, Maibach HI. 1973. Antimicrobials: Experimental contact sensitization in man. J Soc Cosmet Chem 24:399–421.
Mashford PM, Jones AR. 1982. Formaldehyde metabolism by the rat: a re-appraisal. Xenobiotica 12:119–124.6806997
*Matanoski GM. 1991. Risks of pathologists exposed to formaldehyde. DHHS grant no. 5 RO1 OHO1511–03. PB91–173682.
Mathison BH, Harman AE, Bogdanffy MS. 1997. DNA damage in the nasal passageway: a literature review. Mutat Res 380:77–96.9385391
Matsuda H, Ose Y, Nagase H, 1991. Mutagenicity of the components of ozonated humic substance. Sci Total Environ 103:129–140.1882229
Matsuda H, Hibino M, Sato T, 1993a. Mutagenicity of ozonated and chlorinated humic substances. J Environ Sci Health Part A 28:821–837.
Matsuda H, Sato T, Nagase H, 1992. Aldehydes as mutagens formed by ozonation of humic substances. Sci Total Environ 114:205–213.1534420
Matsuda H, Sato T, Nagase H. 1993b. Behavior of mutagenic aldehydes formed by preozonation in postchlorination. J Environ Sci Health Part A 28:1553–1564.
Matsumoto K, Moriya F, Nanikawa R. 1990. The movement of blood formaldehyde in methanol intoxication. II: The movement of blood formaldehyde and its metabolism in the rabbit. Jpn J Legal Med 44(3):205–211.
Matthews TG, Fung KW, Tromberg BJ, 1986. Impact of indoor environmental parameters on formaldehyde concentrations in unoccupied research houses. J Air Pollut Control Assoc 36:1244–1249.3794086
Matthews TG, Hawthorne AR, Thompson CV. 1987. Formaldehyde sorption and desorption characteristics of gypsum wallboard. Environ Sci Technol 21:629–634.19995038
*Matthews TG, Reed TJ, Tromberg BJ, 1985. Formaldehyde emission from combustion sources and solid formaldehyde-resin-containing products: Potential impact on indoor formaldehyde concentrations. In: Gammage RB, Kaye SV, Jacobs VA, ed. Indoor air and human health. Chelsea, MI: Lewis Publishers, Inc., 131–150.
Maurice F, Rivory JP, Bousquet J, 1985. Anaphlyactic shock with formaldehyde [Abstract]. J Allergy Clin Immunol 75:209.
*Maurice F, Rivory JP, Larsson PH, 1986. Anaphylactic shock caused by formaldehyde in a patient undergoing long-term hemodialysis. J Allergy Clin Immunol 77:594–597.3958388
Maut W, Bufalino C, McClure T, 1988. Antagonistic effects in inhaled formaldehyde and ozone on lung injury in resting and exercising rats [Abstract]. FASEB J 2:8723.
McCrae IS, Williams ID. 1994. Road traffic pollution and public nuisance. Sci Total Environ 146/147:81–91.
*McLaughlin JK. 1994. Formaldehyde and cancer: a critical review. Int Arch Occup Environ Health 66:295–301.7896413
McMillan A, Whittemore AS, Silvers A, 1994. Use of biological markers in risk assessment. Risk Anal 14:807–813.7800865
*Meding B, Swanbeck G. 1990. Occupational hand eczema in an industrial city. Contact Dermatitis 22:13–23.2138952
Medinsky MA, Kimbell JS, Morris JB, 1993. Advances in biologically based models for respiratory tract uptake of inhaled volatiles. Fundam Appl Toxicol 20:265–272.8504900
Mendelsohn ML, Moore DHII, Lohman PHM. 1992. A method for comparing and combining short-term genotoxicity test data: Results and interpretation. Mutat Res 266:43–60.1372963
*Menne T, Frosch PJ, Veien NK, 1991. Contact sensitization to 5-chloro-2-methyl-4-isothiazolin-3-one and 2-methyl-4-isothiazolin-3-one (MCI/MI): A European multicentre study. Contact Dermatitis 24:334–341.1893686
Merkle SE. 1985. Ambient concentrations of formaldehyde and ammonia in a screwworm fly rearing facility. Am Ind Hyg Assoc J 46:336–340.4014011
Meyer B. 1986. Formaldehyde exposure from building products. Environ Int 12:283–288.
*Meyer B, Hermanns K. 1985. Reducing indoor air formaldehyde concentrations. J Air Pollut Control Assoc 35:816–821.4045002
Meylan WM, Howard PH. 1991. Bond contribution method for estimating Henry's Law constant. Environ Toxicol Chem 10:1283–1293.
Miampamba M, Chery-Croze S, Chayvialle JA. 1992. Spinal and intestinal levels of substance P, calcitonin gene-related peptide and vasoactive intestinal polypeptide following perendoscopic injection of formalin in rat colonic wall. Neuropeptides 22:73–80.1383864
Miceli JN, Misiak PM. 1986. Air formaldehyde and its association with body burdens. Clin Chem 32:1090.
Migliore L, Ventura L, Barale R, 1989. Micronuclei and nuclear anomalies induced in the gastrointestinal epithelium of rats treated with formaldehyde. Mutagenesis 4:327–334.2687625
*Miller CAIII, Costa M. 1989. Analysis of proteins cross-linked to DNA after treatment of cells with formaldehyde, chromate and cis-diamminechloroplatinum(II). Mol Toxicol 2:11–26.2615769
Miller RG, Kopfler FC, Kelty KC, 1984. The occurrence of aluminum in drinking water. J Am Water Works Assoc 76:84–91.
*Millipore Corporation. 1992. Waters Sep-Pak DNPH-Silica Cartridge. Care and use manual. Milford, MA: Waters Chromatography Publications.
Mills SC, Sharry LF, Cook LJ, 1972. Metabolism of [^14^C]formaldehyde when fed to ruminants as an aldehyde-casein-oil complex. Aust J Biol Sci 25:807–816.5086941
*Milton DK, Walters MD, Hammond K, 1996a. Worker exposure to endotoxin, phenolic compounds, and formaldehyde in a fiberglass insulation manufacturing plant. Am Ind Hyg Assoc J 57:889–896.8865598
Milton DK, Wypij D, Kriebel D, 1996b. Endotoxin exposure-response in a fiberglass manufacturing facility. Am J Ind Med 29:3–13.8808037
*Miyamoto Y. 1986. Eye and respiratory irritants in jet engine exhaust. Aviat Space Environ Med 57:1104–1108.3790031
Mizra MA, Husain K, Misra S. 1987. Carcinogenic effect of formaldehyde in mice: A biochemical and histopathological study. Biol Membr 13:132–136.
Molhave L, Dueholm S, Jensen LK. 1995. Assessment of exposures and health risks related to formaldehyde emissions from furniture: a case study. Indoor Air 5:104–119.
Monks TJ, Anders MW, Dekant W, 1990. Glutathione conjugate mediated toxicities. Toxicol Appl Pharmacol 106:1–19.2251674
Monroe BA, Lee JS, Livingston GK, 1988. Genetic and pulmonary responses to formaldehyde and phenol in anatomy lab [Abstract]. Clin Res 36:347A.
Montanaro A. 1997. Chemically induced nonspecific bronchial hyperresponsiveness. Clin Rev Allergy Immunol 15:187–203.9315411
*Monteiro-Riviere NA, Popp JA. 1986. Ultrastructural evaluation of acute nasal toxicity in the rat respiratory epithelium in response to formaldehyde gas. Fundam Appl Toxicol 6:251–262.3699315
Monticello TM. 1991. Formaldehyde-induced pathology and cell proliferation [Abstract]. Diss Abstr Int B 52:2509–B.
Monticello TM, Morgan KT. 1989. Cell kinetics and characterization of 'preneoplastic' lesions in nasal respiratory epithelium of rats exposed to formaldehyde [Abstract]. Carcinogenesis 30:195.
Monticello TM, Morgan KT. 1994. Cell proliferation and formaldehyde-induced respiratory carcinogenesis. Risk Anal 14:313–319.8029503
Monticello TM, Morgan KT. 1997. Chemically-induced nasal carcinogenesis and epithelial cell proliferation: a brief review. Mutat Res 380:33–41.9385388
Monticello TM, Gross EA, Morgan KT. 1993. Cell proliferation and nasal carcinogenesis. Environ Health Perspect 101(Suppl. 5):121–124.
*Monticello TM, Miller FJ, Morgan KT. 1991. Regional increases in rat nasal epithelial cell proliferation following acute and subchronic inhalation of formaldehyde. Toxicol Appl Pharmacol 111:409–421.1746023
*Monticello TM, Morgan KT, Everitt JI, 1989. Effects of formaldehyde gas on the respiratory tract of Rhesus monkeys. Am J Pathol 134:515–527.2923182
*Monticello TM, Swenberg JA, Gross EA, 1996. Correlation of regional and nonlinear formaldehyde-induced nasal cancer with proliferating populations of cells. Cancer Res 56:1012–1022.8640755
*Mopper K, Stahovec WL. 1986. Sources and sinks of low molecular weight organic carbonyl compounds in seawater. Mar Chem 19:305–321.
*Morgan KT. 1997. A brief review of formaldehyde carcinogenesis in relation to rat nasal pathology and human health risk assessment. Toxicol Pathol 25:291–307.9210261
Morgan KT, Monticello TM. 1990. Airflow, gas deposition, and lesion distribution in the nasal passages. Environ Health Perspect 88:209–218.
*Morgan KT, Gross EA, Patterson DL. 1986a. Distribution, progression, and recovery of acute formaldehyde-induced inhibition of nasal mucociliary function of F-344 rats. Toxicol Appl Pharmacol 86:448–456.3787637
*Morgan KT, Jiang X-Z, Starr TB, 1986b. More precise localization of nasal tumors associated with chronic exposure of F-344 rats to formaldehyde gas. Toxicol Appl Pharmacol 82:264–271.3945953
*Morgan KT, Kimbell JS, Monticello TM, 1991. Studies of inspiratory airflow patterns in the nasal passages of the F344 rat and Rhesus monkey using nasal molds: Relevance to formaldehyde toxicity. Toxicol Appl Pharmacol 110:223–240.1891770
*Morgan KT, Patterson DL, Gross EA. 1986c. Responses of the nasal mucociliary apparatus of F-344 rats to formaldehyde gas. Toxicol Appl Pharmacol 82:1–13.3945936
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5:485–527.
*Moschandreas D, Relwani S, Johnson D, 1986. Emission rates from unvented gas appliances. Environ Int 12:247–253.
Moser J, Bagchi D, Akubue PI, 1993. Excretion of malondialdehyde, formaldehyde, acetaldehyde and acetone in the urine of rats following acute and chronic administration of ethanol. Alcohol Alcohol 28:287–295.8352840
Moura C, Dias M, Vale T. 1994. Contact dermatitis in painters, polishers and varnishers. Contact Dermatitis 31:51–53.7924300
Moye HA, Weintraub RA, Jex GW. 1986. Fate of 1,2-dibromoethane (EDB) in the subsurface environment [Abstract]. Abstr Pap Am Chem Soc 191:ENVR 5.
*Muir PS. 1991. Fogwater chemistry in a wood-burning community, western Oregon. J Air Waste Manage Assoc 41:32–38.1994973
Muller-Herold U, Caderas D, Funck P. 1997. Validity of global lifetime estimates by a simple general limiting law for the decay of organic compounds with long-range pollution potential. Environ Sci Technol 31:3511–3515.
Murphy AP, Boegli WJ, Price MK, 1989. A fenton-like reaction to neutralize formaldehyde waste solutions. Environ Sci Technol 23:166–169.
*Murphy SD, Davis HV, Zaratzian VL. 1964. Biochemical effects in rats from irritating air contaminants. Toxicol Appl Pharmacol 6:520–528.14216993
Nagayama J, Nagayama M. 1993. Frequency of micronuclei induced in cultured lymphocytes by highly toxic organochlorine congeners. Fukuoka Igaku Zasshi 84:189–194.8330835
*Naruse M, Naruse H, Aoyama M. 1995. Determination of formaldehyde in textiles using a diffuse sampler. Bull Environ Contam Toxicol 55:810–816.8601058
NAS/NRC. 1980. Formaldehyde: An assessment of its health effects. Committee on Toxicology, National Research Council, National Academy of Sciences for the Consumer Product Safety Commission, Washington, DC. AD A 087 854, NAS/ACT/P-881A.
*NAS/NRC. 1989. Report of the Oversight Committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy Press, 15–35.
*Natarajan AT, Darroudi F, Bussman CJ M, 1983. Evaluation of the mutagenicity of formaldehyde in mammalian cytogenetic assays in vivo and in vitro. Mutat Res 122:355–360.6656818
Neely WB. 1964. The metabolic fate of formaldehyde-14C intraperitoneally administered to the rat. Biochem Pharmacol 13:1137–1142.14222510
Nelson BK. 1986. Behavioral teratology of industrial solvents. In: Riley EP, Vorhees CV, ed. Handbook of behavioral teratology. New York: Plenum Press, 391–406.
Nelson E. 1996. Laboratory probing of oncogenes from human liquid and solid specimens as markers of exposure to toxicants. Crit Rev Toxicol 26:483–549.8891429
*Nethercott JR, Holness DL. 1988. Contact dermatitis in funeral service workers. Contact Dermatitis 18:263–267.2970932
Nethercott JR, Holness DL, Adams RM, 1994. Multivariate analysis of the effect of selected factors on the elicitation of patch test response to 28 common environmental contactants in North America. Am J Contact Dermatitis 5:13–18.
Newsome JR, Norman V, Keith CH. 1965. Vapor phase analysis of tobacco smoke. Tob Int:102–110.
*NFPA (National Fire Protection Agency). 1994. Fire Protection Guide to Hazardous Materials. 11th ed., Quincy, MA: NFPA, 49–72.
Nilsson C-A, Lindahl R, Norstrom A. 1987. Occupational exposure to chain saw exhausts in logging operations. Am Ind Hyg Assoc J 48:99–105.3565274
NIOSH. 1976. Criteria for a recommended standard. Occupational exposure to formaldehyde. Cincinnati, OH: Department of Health, Education and Welfare, National Institute for Occupational Safety and Health. DHEW (NIOSH) publication no. 77–126.
*NIOSH. 1989a. Manual of analytical methods, 3rd edition. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
*NIOSH. 1989b. NIOSH Recommendations for occupational safety and health: Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute of Occupational Safety and Health.
NIOSH. 1990. Health hazard evaluation report, HETA 88–068-2077. Schmidt Cabinet Company, New Salisbury, Indiana. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. PB91–184515.
*NIOSH. 1992. NIOSH Recommendations for occupational safety and health: Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. (DHHS) NIOSH publication no. 92–100.
*NIOSH. 1994a. Manual of analytical methods, 4th edition. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
*NIOSH. 1994b. Manual of analytical methods, 4th edition. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
*NIOSH. 1994c. NIOSH Pocket guide to chemical hazards. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. DHHS (NIOSH) publication no. 94–116.
NIOSH. 1995a. Recommendations for occupational safety and health: Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute of Occupational Safety and Health.
*NIOSH. 1995b. Formaldehyde numbers of potentially exposed employees. NOSE-Based Job Exposure Matrix. Am J Ind Med 20:163–174.
Nishi K, Yamada M, Wakasugi C. 1988. Formaldehyde poisoning: Report of an autopsy case. Jpn J Legal Med 42(1):85–89.
Niyato-Shirkhodaee F, Shibamoto T. 1992. In vitro determination of toxic aldehydes formed from the skin lipid, triolein, upon ultraviolet irradiation: Formaldehyde and acrolein. J Toxicol Cutaneous Ocul Toxicol 11:285–292.
Noble JS, Strang CR, Michael PR. 1993. A comparison of active and passive sampling devices for full-shift and short-term monitoring of formaldehyde. Am Ind Hyg Assoc J 54:723–732.
Nocentini S, Moreno G, Coppey J. 1980. Survival, DNA synthesis and ribosomal RNA transcription in monkey kidney cells treated by formaldehyde. Mutat Res 70:231–240.6769033
*Nondek L, Milofsky RE, Birks JW. 1991. Determination of carbonyl compounds in air by HPLC using on-line analyzed microcartridges, fluorescence and chemiluminescence detection. Chromatographia 32:33–39.
*Nondek L, Rodier DR, Birks JW. 1992. Measurement of sub-ppb concentrations of aldehydes in a forest atmosphere using a new HPLC technique. Environ Sci Technol 26:1174–1178.
*Norback D, Bjornsson E, Janson C, 1995. Asthmatic symptoms and volatile organic compounds, formaldehyde, and carbon dioxide in dwellings. Occup Environ Med 52:388–395.7627316
*Nordman H, Keskinen H, Tuppurainen M. 1985. Formaldehyde asthma - Rare or overlooked? J Allergy Clin Immunol 75:91–99.3968333
Norman GR, Pengelly LD, Kerigan AT, 1986. Respiratory function of children in homes insulated with urea formaldehyde foam insulation. Can Med Assoc J 134:1135–1138.3697859
*Norsted SW, Kozinetz CA, Annegers JF. 1985. Formaldehyde complaint investigations in mobile homes by the Texas Department of Health. Environ Res 37:93–100.3996345
*NRC. 1981. National Research Council. Formaldehyde and other aldehydes. USEPA 600/6–82-002.
*NRC. 1986. National Research Council. Environmental tobacco smoke: Measuring exposures and assessing health effects. Washington, DC: National Academy Press.
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washinton, DC: National Academy Press.
NTP. 1994. Seventh annual report on carcinogens. Research Triangle Park, NC: U. S. Department of Health and Human Services, Public Health Service, National Toxicology Program, National Institute of Environmental Health Services.
*NTP. 1998. Eighth annual report on carcinogens. Research Triangle Park, NC: U. S. Department of Health and Human Services, Public Health Service, National Toxicology Program, National Institute of Environmental Health Services.
Nunn AJ, Craigen AA, Darbyshire JH, 1990. Six year follow up of lung function in men occupationally exposed to formaldehyde. Br J Ind Med 47:747–752.2245186
O'Connor PM, Fox BW. 1987. Comparative studies of DNA cross-linking reactions following methylene dimethanesulphonate and its hydrolytic product, formaldehyde. Cancer Chemother Pharmacol 19:11–15.3815720
Odeigah PG C. 1997. Sperm head abnormalities and dominant lethal effects of formaldehyde in albino rats. Mutat Res 389:141–148.9093377
Ohtsuka R, Shuto Y, Fujie H, 1997. Response of respiratory epithelium of BN and F344 rats to formaldehyde inhalation. Exp Anim 46:279–286.9353635
Olsen JH, Dossing M. 1982. Formaldehyde induced symptoms in day care centers. Am Ind Hyg Assoc J 43:366–370.7090990
*Olsen JH, Jensen SP, Hink M, 1984. Occupational formaldehyde exposure and increased nasal cancer risk in man. Int J Cancer 34:639–644.6500742
Olson JH, Asnaes S. 1986. Formaldehyde and the risk of squamous cell carcinoma of the sinonasal cavities. Br J Ind Med 43:769–774.3790457
Olson KL, Swarin SJ. 1985. Determination of aldehydes and ketones by derivatization and liquid chromatography-mass spectrometry. J Chromatogr 333:337–347.
OSHA. 1974. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.
*OSHA. 1992. U.S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1048.
*OSHA. 1996. Occupational exposure to formaldehyde. OSHA fact sheet No. 92–27. U.S. Department of Labor, Occupational Safety and Health Administration.
Osinowo OA, Bale JO, Oyedipe EO, 1982. Motility and eosin uptake of formaldehyde-treated ram spermatozoa. J Reprod Fertil 65:389–394.6178824
OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
Otson R, Pellin P. 1988. A review of techniques for measurement of airborne aldehydes. Sci Total Environ 77:95–131.3071846
*Overman DO. 1985. Absence of embryotoxic effects of formaldehyde after percutaneous exposure in hamsters. Toxicol Lett 24:107–110.3975924
Owen BA, Dudney CS, Tan EL, 1990. Formaldehyde in drinking water: Comparative hazard evaluation and an approach to regulation. Regul Toxicol Pharmacol 11:220–236.2196634
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 222–238.
Pabst R. 1987. Exposure to formaldehyde in anatomy: An occupational health hazard? Anat Rec 219:109–112.3688466
Pang SN J. 1995. Final report on the safety assessment of melamine/formaldehyde resin. J Am Coll Toxicol 14:373–385.
*Partanen T. 1993. Formaldehyde exposure and respiratory cancer - a meta-analysis of the epidemiologic evidence. Scand J Work Environ Health 19:8–15.8465176
*Partanen T, Kauppinen T, Hernberg S, 1990. Formaldehyde exposure and respiratory cancer among woodworkers - an update. Scand J Work Environ Health 16:394–400.2284589
*Partanen T, Kauppinen T, Nurminen M, 1985. Formaldehyde exposure and respiratory and related cancers: A case-referent study among Finnish woodworkers. Scand J Work Environ Health 11:409–415.4095518
Patel RN, Hoarke DS. 1971. Physiological studies of methane and methanol-oxidizing bacteria: Oxidation of C-1 compounds by Methylococcus capsulatus. J Bacteriol 107:187–192.5563868
*Patterson R, Dykewicz MS, Evans RIII, 1989. IgG antibody against formaldehyde human serum proteins: A comparison with other IgG antibodies against inhalant proteins and reactive chemicals. J Allergy Clin Immunol 84:359–366.2778242
Patterson R, Harris KE, Grammar LC. 1985. Canine antibodies against formaldehyde-dog serum albumin conjugates: Induction, measurement, and specificity. J Lab Clin Med 106:93–100.4009027
*Patterson R, Pateras V, Grammer LC, 1986. Human antibodies against formaldehyde-human serum albumin conjugates or human serum albumin in individuals exposed to formaldehyde. Int Arch Allergy Appl Immunol 79:53–59.3941010
*Paustenbach D, Alarie Y, Kulle T, 1997. A recommended occupational exposure limit for formaldehyde based on irritation. J Toxicol Environ Health 50:217–263.9055874
Paustenbach DJ, Finley BL, Kacew S. 1996. Biological relevance and consequences of chemical- or metal-induced DNA cross-linking. Proc Soc Exp Biol Med 211:211–217.8633101
*Pazdrak K, Gorski P, Krakowiak A, 1993. Changes in nasal lavage fluid due to formaldehyde inhalation. Int Arch Occup Environ Health 64:515–519.8482593
Pereira MA, Chang LW, McMillan L, 1982. Battery of short-term tests in laboratory animals to corroborate the detection of human population exposures to genotoxic chemicals [Abstract]. Environ Mutagen 4:317.
*Perkins JL, Kimbrough JD. 1985. Formaldehyde exposure in a gross anatomy laboratory. J Occup Med 27:813–815.4067687
*Peters KP, Heese A. 1997. [Formaldehyde and formaldehyde resins - their relevance in reference to textile dermatitis]. Allergologie 20:239–245. (German)
Peterson JE. 1993. Toxic pyrolysis products of solvents, paints, and polymer films. Occup Med State Art Rev 8:533–547.
*Petreas M, Twiss S, Pon D, 1986. A laboratory evaluation of two methods for measuring low levels of formaldehyde in indoor air. Am Ind Hyg Assoc J 4:276–280.
*Pickrell JA, Griffis LC, Mokler BV, 1984. Formaldehyde release from selected consumer products: Influence of chamber loading, multiple products, relative humidity, and temperature. Environ Sci Technol 18:682–686.
*Pickrell JA, Mokler BV, Griffis LC, 1983. Formaldehyde release rate coefficients from selected consumer products. Environ Sci Technol 17:753–757.22283133
*Pin I, Freitag AP, O'Byrne PM, 1992. Changes in the cellular profile of induced sputum after allergen-induced asthmatic responses. Am Rev Respir Dis 145:1265–1269.1595989
Plesner BH, Hansen K. 1983. Formaldehyde and hexamethylenetetramine in Styles' cell transformation assay. Carcinogenesis 4:457–459.6839418
Pocker Y, Li H. 1990. Kinetics and mechanism of methanol and formaldehyde interconversion and formaldehyde oxidation catalyzed by liver alcohol dehydrogenase. Adv Exp Med Biol 284:315–325.
Poitrast BJ, Keller WC, Elves RG. 1988. Estimation of chemical hazards in breast milk. Aviat Space Environ Med 59:A87–A92.3202809
*Polacow I, Cabasso L, Li HJ. 1976. Histone redistribution and conformational effect on chromatin induced by formaldehyde. Biochemistry 15:4559–4565.987800
Pommery J, Mathieu M, Mathieu D, 1993. Atrazine in plasma and tissue following atrazine-aminotriazole-ethylene glycol-formaldehyde poisoning. Clin Toxicol 31:323–331.
Porter DH, Cook RJ, Wagner C. 1985. Enzymatic properties of dimethylglycine dehydrogenase and sarcosine dehydrogenase from rat liver. Arch Biochem Biophys 243:396–407.2417560
Possanzini M, Di Palo V. 1988. Simultaneous measurements of formaldehyde and ozone in air by annular denuder - HPLC techniques. Chromatographia 25:895–898.
*Possanzini M, Ciccioli P, DiPalo V, 1987. Determination of low boiling aldehydes in air and exhaust gases by using annular denuders combined with HPLC techniques. Chromatographia 23:829–834.
*Potter DW, Wederbrand KS. 1995. Total IgE antibody production in BALB/c mice after dermal exposure to chemicals. Fundam Appl Toxicol 26:129–137.
*Prat J, Xaubet A, Mullol J, 1993. Cell content and albumin concentration in nasal lavage from patients with rhinitis. Ann Allergy 70:175–178.8430926
Priha E, Liesivuori J, Santa H, 1996. Reactions of hydrated formaldehyde in nasal mucus. Chemosphere 32:1077–1082.8920592
Proctor BL, Gaulden ME, Dowd MA. 1986. Reactivity and fate of benzene and formaldehyde in culture medium with and without fetal calf serum; relevance to in vitro mutagenicity testing. Mutat Res 160:259–266.3960039
*Pross HF, Day JH, Clark RH, 1987. Immunological studies of subjects with asthma exposed to formaldehyde and urea-formaldehyde foam insulation (UFFI) off products. J Allergy Clin Immunol 79:797–810.2437172
Protasova IA, Semin YA, Adler VV, 1982. Influence of formaldehyde and products of its interaction with amines on processes of DNA transcription in vitro. Biochemistry 47:1509–1521.
*Purchase IF H, Paddle GM. 1989. Does formaldehyde cause nasopharyngeal cancer in man? Cancer Lett 46:79–85.2665934
Quackenboss JJ, Bronnimann D, Camilli AE, 1988. Bronchial responsiveness in children and adults in association with formaldehyde, particulate matter, and environmental tobacco smoke exposures [Abstract]. Am Rev Respir Dis 137:253.3277495
*Quackenboss JJ, Lebowitz MD, Michaud JP, 1989. Formaldehyde exposure and acute health effects study. Environ Int 15:169–176.
*Radford T, Dalsis DE. 1982. Analysis of formaldehyde in shrimp by high pressure-liquid chromatography. J Agric Food Chem 30:600–602.7096813
*Ragan DL, Boreiko CJ. 1981. Initiation of C3H/10T½ cell transformation by formaldehyde. Cancer Lett 13:325–331.7306959
Raiyani CV, Shah SH, Desai NM, 1993. Characterization and problems of indoor pollution due to cooking stove smoke. Atmos Environ 27A:1643–1655.
Randerath K, Reddy MV, Gupta RC. 1981. ^32^P-labeling test for DNA damage. Proc Natl Acad Sci U S A 78:6126–6129.7031643
Ranly DM. 1985. Assessment of the systemic distribution and toxicity of formaldehyde following pulpotomy treatment: part one. J Dent Child 52:431–434.
Rappaport BZ, Hoffman MM. 1941. Urticaria due to aliphatic aldehydes. JAMA,J Am Med Assoc 116:2656–2659.
*Rastogi SC. 1992. A survey of formaldehyde in shampoos and skin creams on the Danish market. Contact Dermatitis 27:235–240.1451488
Razia Beevi M, Radhakrishnan S. 1987. Haematological effects of sublethal concentration of formalin on Sarotherodon mossambicus (Peters). Proc Indian Acad Sci Sect B 96:721–725.
Recio L. 1997. Oncogene and tumor suppressor gene alterations in nasal tumors. Mutat Res 380:27–31.9385387
*Recio L, Sisk S, Pluta L, 1992. p53 mutations in formaldehyde-induced nasal squamous cell carcinomas in rats. Cancer Res 52:6113–6116.1394239
*Reed CE, Frigas E. 1984. Does formaldehyde cause allergic respiratory disease? In: Gammage RB, Kaye SV, Jacobs VA, ed. Indoor air and human health. Chelsea, MI: Lewis Publishers, Inc., 379–386.
*Reiss R, Ryan PB, Tibbetts SJ, 1995. Measurement of organic acids, aldehydes, and ketones in residential environments and their relation to ozone. J Air Waste Manage Assoc 45:811–822.
Rettenmeier AW, Hennings R, Wodarz R. 1993. Determination of butoxyacetic acid and n-butoxyacetyl-glutamine in urine of lacquerers exposed to 2-butoxyethanol. Int Arch Occup Environ Health 65:S151–S153.8406915
Reuzel PG, Wilmer JW, Woutersen RA, 1990. Interactive effects of ozone and formaldehyde on the nasal respiratory lining epithelium in rats. J Toxicol Environ Health 29:279–292.2313740
*Richards LW, Anderson JA, Blumenthal DL, 1983. Hydrogen peroxide and sulfur (IV) in Los Angeles cloud water. Atmos Environ 17:911–914.
*Riedel F, Hasenauer E, Barth PJ, 1996. Formaldehyde exposure enhances inhalative allergic sensitization in the guinea pig. Allergy 51:94–99.8738514
Risch SJ. 1988. Migration of toxicants, flavors and odor-active substances from flexible packaging materials to food. Food Technol 42:95–102.
*Ritchie IM, Lehnen RG. 1987. Formaldehyde-related health complaints of residents living in mobile and conventional homes. Am J Public Health 77:323–328.3812839
*Rithidech K, Au WW, Ramanujam VM S, 1987. Induction of chromosome aberrations in lymphocytes of mice after subchronic exposure to benzene. Mutat Res 188:135–140.3587261
Robbins JD, Norred WP, Bathija A, 1984. Bioavailability in rabbits of formaldehyde from durable-press textiles. J Toxicol Environ Health 14:453–463.6438346
Robert A, Ducos P, Francin JM. 1995. Determination of urinary 4,4'-methylenedianiline and its acetylated metabolites by solid-phase extraction and HPLC analysis with UV and electrochemical detection. Int Arch Occup Environ Health 68:44–51.8847112
Robertson AS, Burge PS, Hedge A, 1985. Comparison of health problems related to work and environmental measurements in two office buildings with different ventilation systems. Br Med J 291:373–376.3926199
Roemer E, Anton HJ, Kindt R. 1993. Cell proliferation in the respiratory tract of the rat after acute inhalation of formaldehyde or acrolein. J Appl Toxicol 13:103–107.8486908
Rohde DS, Detweiler DJ, Basbaum AI. 1997. Formalin-evoked Fos expression in spinal cord is enhanced in morphine-tolerant rats. Brain Res 766:93–100.9359591
Romaguera C, Grimalt F, Lecha M. 1981. Occupational purpuric textile dermatitis from formaldehyde resins. Contact Dermatitis 7:152–153.6456111
Rosen C, Andersson I-M, Juringe L. 1990. Reduction of exposure to solvents and formaldehyde in surface-coating operations in the woodworking industry. Ann Occup Hyg 34:293–303.2372190
Rosenberg J. 1984. Controversies in the assessment of carcinogenic risk of formaldehyde. In: Becker CH, Coye MJ, ed. Cancer prevention: Strategies in the workplace. Washington, DC: Hemisphere Publishing Corporation, 147–152.
*Ross WE, Shipley N. 1980. Relationship between DNA damage and survival in formaldehyde-treated mouse cell. Mutat Res 79:277–283.7219432
Ross WE, McMillan DR, Ross CF. 1981. Comparison of DNA damage by methymelamines and formaldehyde. J Natl Cancer Inst 67:217–221.6788992
Rostenberg AJ, Bairstow B, Luther TW. 1952. A study of eczematous sensitivity to formaldehyde. J Invest Dermatol 19:459–462.13023018
Roto P, Sala E. 1996. Occupational laryngitis caused by formaldehyde: A case report. Am J Ind Med 29:275–277.8833780
*Roush GC, Walrath J, Stayner LT, 1987. Nasopharyngeal cancer, sinonasal cancer, and occupations related to formaldehyde: A case-control study. J Natl Cancer Inst 79:1221–1224.3480373
Rudolf W. 1994. Concentration of air pollutants inside cars driving on highways and in downtown areas. Sci Total Environ 146/147:433–444.
*Rudzki E, Rebandel P, Grzywa Z. 1989. Patch tests with occupational contactants in nurses, doctors and dentists. Contact Dermatitis 20:247–259.2526710
*Rusch GM, Clary JJ, Rinehart WE, 1983. A 26-week inhalation toxicity study with formaldehyde in the monkey, rat, and hamster. Toxicol Appl Pharmacol 68:329–343.6857667
Rycroft RJ G. 1986. Occupational dermatoses among office personnel. Occup Med State Art Rev 1:323–328.
Rylander R. 1974. Pulmonary cell responses to inhaled cigarette smoke. Arch Environ Health 29:329–333.4279631
Sachs K, Pindel B, Jastrzqb J, 1995. [Histology of respiratory system after exposition on bacterial infection and formalin vapouries inducing experimental bronchospasm]. Pneumol Alergol Pol 63:259–263. (Polish)
*Saillenfait AM, Bonnet P, deCeaurriz J. 1989. The effects of maternally inhaled formaldehyde on embryonal and foetal development in rats. Food Chem Toxicol 27:545–548.2792978
Saladino AJ, Willey JC, Lechner JF, 1985. Effects of formaldehyde, acetaldehyde, benzoyl peroxide, and hydrogen peroxide on cultured normal human bronchial epithelial cells. Cancer Res 45:2522–2526.3986791
*Salas LJ, Singh HB. 1986. Measurements of formaldehyde and acetaldehyde in the urban ambient air. Atmos Environ 20:1301–1304.
*Saldiva PH N, do Rio Caldera MP, Massad E, 1985. Effects of formaldehyde and acetaldehyde inhalation on rat pulmonary mechanics. J Appl Toxicol 5:288–292.4056306
Salkie ML. 1991. The prevalence of atopy and hypersensitivity to formaldehyde in pathologists. Arch Pathol Lab Med 115:614–616.2039347
Sanchez I, Rodreguez F, Quinones D, 1997. Occupational dermatitis due to formaldehyde in newspaper. Contact Dermatitis 37:131–132.9330824
Sander JE, Steffens WL. 1997. Transmission electron microscopic demonstration of abnormalities on the tracheal cilia of chicks exposed to formaldehyde during hatching. Avian Dis 41:977–980.9454936
Sarrif AM, Donovan SM, Stewart JA, 1983. Inhibition by semicarbazide of the mutagenic activities of formaldehyde (HCHO) and hexamethyphosphoramide (HMPA) in Salmonella typhimuriam reverse suspension assay [Abstract]. Environ Mutagen 5:476.
Sass-Kortsak AM, Holness DL, Pilger CW, 1986. Wood dust and formaldehyde exposures in the cabinet-making industry. Am Ind Hyg Assoc J 47:747–753.3799474
*Sauder LR, Chatham MD, Green DJ, 1986. Acute pulmonary response to formaldehyde exposure in healthy nonsmokers. J Occup Med 28:420–424.3723214
Sauder LR, Green DJ, Chatham MD, 1987. Acute pulmonary response of asthmatics to 3.0 ppm formaldehyde. Toxicol Ind Health 3:569–577.3433289
*Schachter EN, Witek TJ J, Brody DJ, 1987. A study of respiratory effects from exposure to 2.0 ppm formaldehyde in occupationally exposed workers. Environ Res 44:188–205.3691441
Schachter EN, Witek TJ, Tosun T, 1985. Respiratory effects of exposure to 2.0 ppm of formaldehyde in asthmatic subjects [Abstract]. Am Rev Respir Dis 131:A170.
*Schachter EN, Witek TJ J, Tosun T, 1986. A study of respiratory effects from exposure to 2 ppm formaldehyde in healthy subjects. Arch Environ Health 41:229–239.3767432
Schardein JL, Keller KA. 1989. Potential human developmental toxicants and the role of animal testing in their identification and characterization. CRC Crit Rev Toxicol 19:251–339.
Schiff HI, Mackey GI, Mayne LK, 1986. Tunable diode laser absorption spectrometer measurement of HNO_3_, HCHO and NO_2_ and luminox NO_2_ measurements in Claremont CA, September 1985 [Abstract]. Abstr Pap Am Chem Soc 192:ENVR 112.
Schiwara HW, Siegel H, Goebel A. 1992. Increase and decrease in formic acid concentration in urine samples stored at room temperature. Eur J Clin Chem Clin Biochem 30:75–79.1581412
*Schmid E, Googelmann W, Bauchinger M. 1986. Formaldehyde-induced cytotoxic, genotoxic and mutagenic response in human lymphocytes and Salmonella typhimurium. Mutagenesis 1:427–431.3331682
Schnuch A, Geier J. 1997. [Sensitization to formaldehyde - Results from the Information Network of Departments of Dermatology (IVDK) 1992–1995]. Allergologie 20:205–214. (German) [Translation in progress].
*Schorr WF, Keran E, Plotka E. 1974. Formaldehyde allergy: The quantitative analysis of American clothing for free formaldehyde and its relevance in clinical practice. Arch Dermatol 110:73–76.4278440
Schuck EA, Stephens ER, Middleton JT. 1966. Eye irritation response at low concentrations of irritants. Arch Environ Health 13:570–575.5925628
*Schulam P, Newbold R, Hull LA. 1985. Urban and rural ambient air aldehyde levels in Schenectady, New York and on Whiteface Mountain, New York. Atmos Environ 19:623–626.
Schulz P, Jones JL, Patten BM. 1988. Encephalopathy and rhabdomyolysis from ingesting formaldehyde-dipped cigarettes [Abstract]. Neurology 38:207.3340281
Scott CS, Margosches EH. 1985. Cancer epidemiology relevant to formaldehyde. J Environ Sci Health C C 3:107–144.
Scott MJ, Ward JB J, Dallas CE, 1985. Chromosome damage observed in lung but not bone marrow of Sprague-Dawley rats exposed to formaldehyde by inhalation [Abstract]. Environ Mutagen 7:53.3967634
*Seiber JN. 1996. Toxic air contaminants in urban atmospheres: Experience in California. Atmos Environ 30:751–756.
*Seidenberg JM, Becker RA. 1987. A summary of the results of 55 chemicals screened for developmental toxicity in mice. Teratogenesis Carcinog Mutagen 7:17–28.2884740
Seidenberg JM, Anderson DG, Becker RA. 1986. Validation of an in vivo developmental toxicity screen in the mouse. Teratogenesis Carcinog Mutagen 6:361–374.2878502
*Sellakumar AR, Snyder CA, Solomon JJ, 1985. Carcinogenicity of formaldehyde and hydrogen chloride in rats. Toxicol Appl Pharmacol 81:401–406.4082190
Senichenkova IN, Chebotar NA. 1996. Effects of gasoline and formaldehyde on prenatal development of rats with induced iron microelementosis. Ontogenez 27:90–94.
*Setchell BP, Waites GM H. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of Physiology: Endocrinology V. Washington, DC: American Physiological Society.
Sexton K, Liu K-S, Petras MX. 1986. Formaldehyde concentrations inside private residences: A mail-out approach to indoor air monitoring. J Air Pollut Control Assoc 36:698–704.3734250
*Sexton K, Petreas MX, Liu KS. 1989. Formaldehyde exposures inside mobile homes. Environ Sci Technol 23:985–988.
Shah BM, Vachhrajani KD, Chinoy NJ, 1987. Formaldehyde induced structural and functional changes in the testis of rats. J Reprod Comp Endocrinol 7:42–52.
*Shah J, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air. Environ Sci Technol 22:1381–1388.22200458
*Shaham J, Bomstein Y, Meltzer A, 1996a. DNA-protein crosslinks, a biomarker of exposure to formaldehyde - in vitro and in vivo studies. Carcinogenesis 17:121–125.8565120
*Shaham J, Bomstein Y, Meltzer A, 1996b. Response. [Letter]. Carcinogenesis 17:2098–2101.
*Shara MA, Dickson PH, Bagchi D, 1992. Excretion of formaldehyde, malondialdehyde, acetaldehyde and acetone in the urine of rats in response to 2,3,7,8-tetrachlorodibenzo-p-dioxin, paraquat, endrin and carbon tetrachloride. J Chromatogr 576:221–233.1400710
Shaver CS, Tong T. 1991. Chemical hazards to agricultural workers. Occup Med 6:391–413.1948526
Sheppard D, Eschenbacher WL, Epstein J. 1984. Lack of bronchomotor response to up to 3 ppm formaldehyde in subjects with asthma. Environ Res 35:133–139.6489284
Shiba M, Marchok AC, Klein-Szanto AJ P, 1987. Pathological changes induced by formaldehyde in open-ended rat tracheal implants preexposed to benzo(a)pyrene. Toxicol Pathol 15:401–408.3432939
*Shrivastaw KP, Singh S. 1995. A new method for spectrophotometric determination of formaldehyde in biologicals. Biologicals 23:47–53.7619435
Shusterman D. 1992. Critical review: The health significance of environmental odor pollution. Arch Environ Health 47:76–87.1540008
Sigsby JE J, Tejada S, Ray W. 1987. Volatile organic compound emissions from 46 in-use passenger cars. Environ Sci Technol 21:466–475.22296134
*Sills JB, Allen JL. 1979. Residues of formaldehyde undetected in fish exposed to formalin. Prog Fish Cult 41:67–68.
Sills RD, Blakeslee PA. 1992. The environmental impact of deicers in airport stormwater runoff. In: 'Itri FM, ed. Chemical Deicers and the Environment. Boca Raton, FL: Lewis Publishers, 323–340.
Sim VM, Pattle RE. 1957. Effect of possible smog irritants on human subjects. JAMA,J Am Med Assoc 165:1908–1913.
Singer B, Kusmierek JT. 1982. Chemical mutagenesis. Annu Rev Biochem 52:655–693.
*Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16:872–880.22236265
Sipilainen-Malm T, Latva-Kala K, Tikkanen L, 1997. Purity of recycled fibre-based materials. Food Addit Contam 14:695–703.9373533
Sisk S, Pluta L, Recio L. 1993. Molecular analysis of P53 mutation in formaldehyde-induced rat nasal squamous cell carcinomas [Abstract]. Environ Mol Mutagen 21:66.
*Skisak CM. 1983. Formaldehyde vapor exposures in anatomy laboratories. Am Ind Hyg Assoc J 44:948–950.6660195
Smedley J. 1996. Is formaldehyde an important cause of allergic respiratory disease? Clin Exp Allergy 26:247–249.8729659
Smith KA J, Williams PL, Middendorf PJ, 1984. Kidney dialysis: Ambient formaldehyde levels. Am Ind Hyg Assoc J 45:48–50.6702598
Smith MW, Miyashita M, Phelps PC, 1989. The effect of formaldehyde on cytosolic Ca^2+^ of transformed human bronchial epithelial cells as measured by digital imaging fluorescence microscopy. Proc Am Assoc Cancer Res 30:107.
Smyth HF J, Seaton J, Fischer L. 1941. The single dose toxicity of some glycols and derivatives. J Ind Hyg Toxicol 23:259–268.
Sneddon IB. 1968. Dermatitis in an intermittent haemodialysis unit. Br Med J 1:183–184.
Snipes MB, Spoo JE, Brookins LK, 1991. A method for measuring nasal and lung uptake of inhaled vapor. Fundam Appl Toxicol 16:81–91.2019353
Snow R, Baker L, Crews W, 1989. Characterization of emissions from a methanol fueled motor vehicle. J Air Pollut Control Assoc 39:48–54.
*Snyder RD, Van Houten B. 1986. Genotoxicity of formaldehyde and an evaluation of its effects on the DNA repair process in human diploid fibroblasts. Mutat Res 165:21–30.2417114
Socie EM, Gromen KD, Migliozzi AA, 1997. Work-related skin disease in the plastics industry. Am J Ind Med 31:545–550.9099355
*Soffritti M, Maltoni C, Maffei F, 1989. Formaldehyde: An experimental multipotential carcinogen. Toxicol Ind Health 5:699–730.2815102
Sorg BA, Willis JR, Nowatka TC, 1996. Proposed animal neurosensitization model for multiple chemical sensitivity in studies with formalin. Toxicology 111:135–145.8711729
Sorg BA, Willis JR, See RE, 1998. Repeated low-level formaldehyde exposure produces cross-sensitization to cocaine: Possible relevance to chemical sensitivity in humans. Neuropsychopharmacology 18:385–394.9536452
Soro L, Brouh T, Sissoko J, 1997. [Oral formol intoxication. A case report]. Urg Med 16:153–155. (French)
Sparks PJ, Simon GE, Katon WJ, 1990. An outbreak of illness among aerospace workers. West J Med 153:28–33.2098006
Spector I. 1985. AMP: A new form of marijuana. J Clin Psychiatry 46:498–499.4055712
Speese RE. 1983. Anaerobic biotechnology for industrial wastewater treatment. Environ Sci Technol 17:416A–427A.
*Spicer CW, Buxton BE, Holdren MW, 1996. Variability of hazardous air pollutants in an urban area. Atmos Environ 30:3443–3456.
Spoo JW, Rogers RA, Monteiro-Riviere NA. 1992. Effects of formaldehyde, DMSO, benzoyl peroxide, and sodium lauryl sulfate on isolated perfused porcine skin. In Vitro Toxicol 5:251–260.
SRC. 1994a. Syracuse Research Corporation. Henry's Law Constant Program (HENRYWIN, Version 2.50, Serial H0142). Chemical Hazard Assessment Division, Environmental Chemistry Center, Syracuse, NY.
SRC. 1994b. Syracuse Research Corporation. Aqueous Hydrolysis Rate Program (HYDROWIN, Version 1.50a, Serial HY0126). Chemical Hazard Assessment Division, Environmental Chemistry Center, Syracuse, NY.
SRC. 1995a. Syracuse Research Corporation. Atmospheric Oxidation Program (AOPWIN, Version 1.65, Serial 0156). Chemical Hazard Assessment Division, Environmental Chemistry Center, Syracuse, NY.
*SRC. 1995b. Syracuse Research Corporation. Octanol-Water Partition Coefficient Program (KOWWIN, Version 1.37, Serial L0148). Chemical Hazard Assessment Division, Environmental Chemistry Center, Syracuse, NY.
*SRI. 1988. Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute International, 668.
*SRI. 1990. Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute International, 675–676.
*SRI. 1992. Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute International, pp. 677–678.
SRI. 1995. Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute International, 654–655.
*SRI. 1997. Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute International, 649.
*Staffelbach T, Neftel A, Stauffer B, 1991. A record of the atmospheric methane sink from formaldehyde in polar ice cores. Nature 349:603–605.
Stankowski LF, Tuman WG, Godek EG, 1986. Induction of mammalian cell mutations by formaldehyde [Abstract]. Environ Mutagen 8:81.
Staples RE. 1983. Teratogenicity of formaldehyde. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 51–59.
Stark A. 1990. Formaldehyde. In: Haddad LM, Winchester JF, ed. Clinical management of poisoning and drug overdose. Philadelphia, PA: W.B. Saunders Company, 537–541.
Starr TB, Buck RD. 1984. The importance of delivered dose in estimating low-dose cancer risk from inhalation exposure to formaldehyde. Fundam Appl Toxicol 4:740–753.6510605
Starr TB, Gibson JE. 1985. The mechanistic toxicology of formaldehyde and its implications for quantitative risk estimation. Annu Rev Pharmacol Toxicol 25:745–767.3890715
*Stayner L, Smith AB, Reeve G, 1985a. Proportionate mortality study of workers in the garment industry exposed to formaldehyde [Letter]. Am J Ind Med 8:75–76.4025341
*Stayner L, Smith AB, Reeve G, 1985b. Proportionate mortality study of workers in the garment industry exposed to formaldehyde. Am J Ind Med 7:229–240.3985015
*Stayner LT, Elliott L, Blade L, 1988. A retrospective cohort mortality study of workers exposed to formaldehyde in the garment industry. Am J Ind Med 13:667–681.3389362
St. Clair MBG, Gross EA, Morgan KT. 1990. Pathology and cell proliferation induced by intra-nasal instillation of aldehydes in the rat: Comparison of glutaraldehyde and formaldehyde. Toxicol Pathol 18:353–361.2125143
*Sterling TD, Weinkam JJ. 1989. Reanalysis of lung cancer mortality in a National Cancer Institute study on "Mortality among industrial workers exposed to formaldehyde". Exp Pathol 37:128–132.2637142
Sterling TD, Weinkam JJ. 1994. Mortality from respiratory cancers (including lung cancer) among workers employed in formaldehyde industries. Am J Ind Med 25:593–602.8010300
*Sterling TD, Weinkam JJ. 1995. Comments on the Blair and Stewart comments on the Sterling and Weinkam analysis of data from the National Cancer Institute formaldehyde study. Am J Ind Med 27:301–305.7755019
*Sterling TD, Collett CW, Sterling EM. 1987. Environmental tobacco smoke and indoor air quality in modern office work environments. J Occup Med 29:57–61.3546636
*Stern FB, Beaumont JJ, Halperin WE, 1987. Mortality of chrome leather tannery workers and chemical exposures in tanneries. Scand J Work Environ Health 13(S1):108–117.3602964
Stewart PA, Blair A. 1994. Women in the formaldehyde industry: Their exposures and their jobs. J Occup Med 36:918–923.7807276
*Stock TH. 1987. Formaldehyde concentrations inside conventional housing. J Air Pollut Control Assoc 37:913–918.
Storrs FJ, Rosenthal LE, Adams RM, 1989. Prevalence and relevance of allergic reactions in patients patch tested in North America - 1984 to 1985. J Am Acad Dermatol 20:1038–1045.2754054
Strittmatter P, Ball EG. 1955. Formaldehyde dehydrogenase, a glutathione-dependent enzyme system. J Biol Chem 213:445–461.14353946
Strom JG, Jun HW. 1993. Effect of urine pH and ascorbic acid on the rate of conversion of methenamine to formaldehyde. Biopharm Drug Dispos 14:61–69.8427945
*Stroup NE, Blair A, Erikson GE. 1986. Brain cancer and other causes of death in anatomists. J Natl Cancer Inst 77:1217–1224.3467114
Strubelt O, Brasch H, Pentz R, 1990. Experimental studies on the acute cardiovascular toxicity of formalin and its antidotal treatment. Clin Toxicol 28:221–233.
Strubelt O, Younes M, Pentz R, 1989. Mechanistic study on formaldehyde-induced hepatotoxicity. J Toxicol Environ Health 27:351–366.2754759
Stump FD, Knapp K T, Ray WD, 1992. The composition of motor vehicle organic emissions under elevated temperature summer driving conditions (75 to 105 degrees F) - part II. J Air Waste Manage Assoc 42:1328–1335.
*Stumpf JM, Blehm KD, Buchan RM, 1986. Characterization of particleboard aerosol - size distribution and formaldehyde content. Am Ind Hyg Assoc J 47:725–730.3799471
Stutts MJ, Gatzy JT, Knowles MR, 1986. Effects of formaldehyde on bronchial ion transport. Toxicol Appl Pharmacol 82:360–367.3945962
*Su F, Calvert G, Shaw JH. 1979. Mechanism of the photooxidation of gaseous formaldehyde. J Phys Chem 83:3185–3191.
*Subramaniam RP, Richardson RB, Morgan KT, 1998. Computational fluid dynamics simulations of inspiratory airflow in the human nose and nasopharynx. Inhal Toxicol 10:473–502.
Summerhyas J. 1991. Evaluation of risks from urban air pollutants in the Southeast Chicago area. J Air Waste Manage Assoc 41:844–850.1910752
Sun H, Feigal RJ, Messer HH. 1990. Cytotoxicity of glutaraldehyde and formaldehyde in relation to time of exposure and concentration. Pediatr Dent 12:303–307.2128894
*Swann RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
Swenberg JA, Heck Hd'A, Morgan KT, 1985. A scientific approach to formaldehyde risk assessment. In: Hoel DG, Merrill RA, Perera FP, ed. Risk quantitation and regulatory policy. Cold Spring Harbor, New York: Cold Spring Harbor Laboratory, 255–267.
*Swenberg JA, Kerns WD, Mitchell RI, 1980. Induction of squamous cell carcinomas of the rat nasal cavity by inhalation exposure to formaldehyde vapor. Cancer Res 40:3398–3402.7427950
*Swiecichowski AL, Long KJ, Miller ML, 1993. Formaldehyde-induced airway hyperreactivity in vivo and ex vivo in guinea pigs. Environ Res 61:185–199.8495661
Symington P, Coggon D, Holgate S. 1991. Respiratory symptoms in children at schools near a foundry. Br J Ind Med 48:588–591.1911400
Szabad J, Soos I, Polgar G, 1983. Testing the mutagenicity of malondialdehyde and formaldehyde by the drosophila mosaic and the sex-linked recessive lethal tests. Mutat Res 113:117–133.6403850
*Takahashi K, Morita T, Kawazoe Y. 1985. Mutagenic characteristics of formaldehyde on bacterial systems. Mutat Res 156:153–161.3889633
*Takahashi M, Hasegawa R, Furukawa F, 1986a. Effects of ethanol, potassium metabisulfite, formaldehyde and hydrogen peroxide on gastric carcinogenesis in rats after initiation with n-methyl-n nitro-n-nitrosoguanidine. Jpn J Cancer Res 77:118–124.3082823
Takahashi M, Niizuma K, Ohkido M, 1986b. [A case of occupational contact dermatitis due to preservatives, surfactants and raw materials of detergents and wax. Dermatitis and skin patch: VIII, Osaka, Japan]. Skin Res 29:24–34. (Japanese)
Takami M, Kasuya I, Mizumoto K, 1988. A receptor for formaldehyde-treated serum albumin on human placental brush-border membrane. Biochim Biophys Acta 945:291–297.2847791
Tams IP, Bryson DD. 1987. Respiratory symptoms and function in a group of workers manufacturing formaldehyde [Abstract]. Bull Eur Physiopathol Respir 23:332 s.
Tani T, Horiguchi Y. 1990. Effects of formaldehyde on cardiac function. Jpn J Pharmacol 52:563–572.2342227
Tani T, Kogi K, Horiguchi Y. 1986. Inhibitory effects of formaldehyde inhalation on the cardiovascular and respiratory systems in unanesthetized rabbits. Jpn J Pharmacol 40:551–559.3735804
*Tarkowski M, Gorski P. 1995. Increased IgE antiovalbumin level in mice exposed to formaldehyde. Int Arch Allergy Immunol 106:422–424.7719158
Taskinen H, Kyyronen P, Hemminki K, 1994. Laboratory work and pregnancy outcome. J Occup Med 36:311–319.8195901
Temcharoen P, Thilly WG. 1983. Toxic and mutagenic effects of formaldehyde in Salmonella typhimurium. Mutat Res 119:89–93.6338371
Tephly TR. 1991. The toxicity of methanol. Life Sci 48:1031–1041.1997785
Teschke K, Morgan MS, Checkoway H, 1997. Surveillance of nasal and bladder cancer to locate sources of exposure to occupational carcinogens. Occup Environ Med 54:443–451.9245952
Thomas TL, Waxweiler RJ. 1986. Brain tumors and occupational risk factors. Scand J Work Environ Health 12:1–15.
*Thomson EJ, Shackleton S, Harrington JM. 1984. Chromosome aberrations and sister-chromatid exchange frequencies in pathology staff occupationally exposed to formaldehyde. Mutat Res 141:89–93.6493271
Thomson VE, Jones A, Haemisegger E, 1985. The air toxics problem in the United States: An analysis of cancer risks posed by selected air pollutants. J Air Pollut Control Assoc 35:535–540.4008749
Thornton-Manning JR, Dahl AR. 1997. Metabolic capacity of nasal tissue interspecies comparisons of xenobiotic-metabolizing enzymes. Mutat Res 380:43–59.9385389
Thornton-Manning JR, Nikula KJ, Hotchkiss JA, 1997. Nasal cytochrome P450 2A: Identification, regional localization, and metabolic activity toward hexamethylphosphoramide, a known nasal carcinogen. Toxicol Appl Pharmacol 142:22–30.9007030
Thrasher JD, Broughton A, Gard Z. 1988a. Indoor formaldehyde and the elderly. Clin Gerontol 7:63–66.
*Thrasher JD, Broughton A, Micevich P. 1988b. Antibodies and immune profiles of individuals occupationally exposed to formaldehyde six case reports. Am J Ind Med 14:479–488.2973232
*Thrasher JD, Broughton A, Madison R. 1990. Immune activation and autoantibodies in humans with long-term inhalation exposure to formaldehyde. Arch Environ Health 45:217–223.2400243
*Thrasher JD, Madison R, Broughton A, 1989. Building-related illness and antibodies to albumin conjugates of formaldehyde, toluene diisocyanate, and trimellitic anhydride. Am J Ind Med 15:187–196.2543217
*Thrasher JD, Wojdani A, Cheung G, 1987. Evidence for formaldehyde antibodies and altered cellular immunity in subjects exposed to formaldehyde in mobile homes. Arch Environ Health 42:347–350.3439811
Til HP, Woutersen RA, Feron VJ, 1988a. Sub-acute (4-week) oral toxicity of acetaldehyde and formaldehyde in rats [Abstract]. Hum Toxicol 7:86.
*Til HP, Woutersen RA, Feron VJ, 1988b. Evaluation of the oral toxicity of acetaldehyde and formaldehyde in a 4-week drinking-water study in rats. Food Chem Toxicol 26:447–452.3391468
*Til HP, Woutersen VJ, Feron V, 1989. Two-year drinking-water study of formaldehyde in rats. Food Chem Toxicol 27:77–87.2714719
Tinnerberg H, Skarping G, Dalene M, 1995. Test chamber exposure of humans to 1,6-hexamethylene diisocyanate and isophorone diisocyanate. Int Arch Occup Environ Health 67:367–374.8567087
Titenko-Holland N, Levine AJ, Smith MT, 1996. Quantification of epithelial cell micronuclei by fluorescence in situ hybridization (FISH) in mortuary science students exposed to formaldehyde. Mutat Res 37:237–248.
*Tobe M, Natio K, Kurokawa Y. 1989. Chronic toxicity study on formaldehyde administered orally to rats. Toxicology 56:79–86.2728008
Todhunter JA. 1985. Formaldehyde: Refining the risk assessment. In: Turoski V, ed. Formaldehyde: Analytical chemistry and toxicology. Washington, DC: American Chemical Society, 357–373.
*Tomkins BA, McMahon JM, Caldwell WM, 1989. Liquid chromatographic determination of total formaldehyde in drinking water. J Assoc Off Anal Chem 72:835–839.2808246
*Traynor GW, Girman JR, Apte MG, 1985. Indoor air pollution due to emissions from unvented gas-fired space heaters. J Air Pollut Control Assoc 35:231–237.3989114
TRI93. 1995. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI96. 1998. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Triebig G, Zober MA. 1984. Indoor air pollution by smoke constituents - a survey. Prev Med 13:570–581.6399372
Triebig G, Schaller K-H, Beyer B, 1989. Formaldehyde exposure at various workplaces. Sci Total Environ 79:191–195.2727671
Tsuchiya K, Hayashi Y, Onodera M, 1975. Toxicity of formaldehyde in experimental animals - concentrations of the chemical in the elution from dishes of formaldehyde resin in some vegetables. Keio J Med 24:19–37.1123864
Tsuchiya S, Kondo M, Okamoto K, 1985. The cumulative contact enhancement test. Curr Probl Dermatol 14:208–219.4064746
Uba G, Pachorek D, Bernstein J, 1989. Prospective study of respiratory effects of formaldehyde among healthy and asthmatic medical students. Am J Ind Med 15:91–101.2929612
Ueng T-H, Ueng Y-F, Chand T-L, 1993. Induction of cytochrome P450-dependent monooxygenases in hamster tissues by fasting. Toxicol Appl Pharmacol 119:66–73.8470125
*Universities Associated for Research and Education in Pathology. 1988. Epidemiology of chronic occupational exposure to formaldehyde: Report of the ad hoc panel on health aspects of formaldehyde. Toxicol Ind Health 4:77–90.3291203
Upreti RK, Farooqui MY H, Ahmed AE, 1987. Toxicokinetics and molecular interaction of [^14^C]-formaldehyde in rats. Arch Environ Contam Toxicol 16:263–273.3592753
Ura H, Nowak P, Litwin S, 1989. Effects of formaldehyde on normal xenotransplanted human tracheobronchial epithelium. Am J Pathol 134:99–106.2913828
*U.S. Congress 1986. Superfund Amendments and Reauthorization Act of 1986. Ninety-ninth Congress of the United States of America.
*U.S. Congress 1990. Clean Air Act Amendments. Title III, hazardous air pollutants, section 112, hazardous air pollutants as amended, October 26, 1990. One hundred and first Congress of the United States of America, 2nd session Report 101–952.
*Valencia R, Mason JM, Zimmering S. 1989. Chemical mutagenesis testing in Drosophila. VI. Interlaboratory comparison of mutagenicity tests after treatment of larvae. Environ Mol Mutagen 14:238–244.2511011
Vargova M, Janota S, Karelova J, 1992. Analysis of the health risk of occupational exposure to formaldehyde using biological markers. Analusis 20:451–454.
*Vargova M, Wagnerova J, Liskova A, 1993. Subacute immunotoxicity study of formaldehyde in male rats. Drug Chem Toxicol 16:255–275.8404546
*Vasudeva N, Anand C. 1996. Cytogenetic evaluation of medical students exposed to formaldehyde vapor in the gross anatomy dissection level. J Am Coll Health 44:177–179.8583043
*Vaughn TL, Strader C, Davis S, 1986a. Formaldehyde and cancers of the pharynx, sinus and nasal cavity: I. Occupational exposures. Int J Cancer 38:677–683.3770995
*Vaughn TL, Strader C, Davis S, 1986b. Formaldehyde and cancers of the pharynx, sinus and nasal cavity: II. Residential exposures. Int J Cancer 38:685–688.3770996
Venkatakrishan-Bhatt H, Panchal GM. 1992. In vitro study of rat uterus after chronic formaldehyde exposure. Indian J Exp Biol 30:901–903.1293016
*Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold.
Victorin K, Stahlberg M, Alsberg T, 1988. Emission of mutagenic, irritating and odorous substances from gasoline fueled vehicles with different control substances. Chemosphere 17:1767–1780.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vojdani A, Ghoneum M, Brautbar N. 1992. Immune alteration associated with exposure to toxic chemicals. Toxicol Ind Health 8:239–254.1455435
von Hippel P, Wong K-Y. 1971. Dynamic aspects of native DNA structure: Kinetics of the formaldehyde reaction with calf thymus DNA. J Mol Biol 61:587–613.5167307
*Wahlberg JE. 1993. Measurement of skin-fold thickness in the guinea pig. Assessment of edema-inducing capacity of cutting fluids, acids, alkalis, formalin and dimethyl sulfoxide. Contact Dermatitis 28:141–145.8462289
Walker AP. 1985. A more realistic animal technique for predicting human eye response. Food Chem Toxicol 23:175–178.4040060
*Walrath J, Fraumeni JF J. 1983. Proportionate mortality among New York embalmers. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 227–236.
*Walrath J, Fraumeni JF J. 1984. Cancer and other causes of death among embalmers. Cancer Res 44:4638–4641.6467219
*Wang D, Clement P, Smitz J, 1995. Concentrations of chemical mediators in nasal secretions after nasal allergen challenges in atopic patients. Eur Arch Oto-rhino-laryngol 252:S40–S43.
*Wantke F, Demmer CM, Tappler P, 1996a. Exposure to gaseous formaldehyde induces IgE-mediated sensitization to formaldehyde in school-children. Clin Exp Allergy 26:276–280.8729664
*Wantke F, Focke M, Hemmer W, 1996b. Formaldehyde and phenol exposure during an anatomy dissection course: a possible source of IgE-mediated sensitization? Allergy 51:837–841.8947343
Wantke F, Hemmer W, Haglmuller T, 1995. Anaphylaxis after dental treatment with a formaldehyde-containing tooth-filling material. Allergy 50:274–276.7677244
Ward EM, Burnett CA, Ruder A, 1997. Industries and cancer. Cancer Causes Control 8:356–370.9498899
*Ward JB J, Hokanson JA, Smith ER, 1984. Sperm count, morphology and fluorescent body frequency in autopsy service workers exposed to formaldehyde. Mutat Res 130:417–424.6513969
Ward JB J, Legator MS, Chang LW, 1983. Evaluation of occupational exposure to formaldehyde using a battery of tests for genetic damage. Environ Mutagen 5:433–434.
*Weber-Tschopp A, Fischer T, Grandjean E. 1977. [Irritating effects of formaldehyde on men]. Int Arch Occup Environ Health 39:207–218. (German)562325
Weiler E, Apfelbach R. 1992. Age-related differences in olfactory sensitivity in Wistar rats after low-level formaldehyde gas exposure [Abstract]. Chem Senses 17:717–718.
*Weschler CJ, Shields HC. 1996. Production of the hydroxyl radical in indoor air. Environ Sci Technol 30:3250–3258.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*West S, Hildesheim A, Dosemeci M. 1993. Non-viral risk factors for nasopharyngeal carcinoma in the Philippines: Results from a case-control study. Int J Cancer 55:722–727.7503957
*WHO. 1989. World Health Organization. Formaldehyde: Environmental health criteria. Geneva: World Health Organization.
*Widdowson EM, Dickerson JW T. 1964. Chapter 17: Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wiegand MS. 1997. Volatile organic compound emissions from a recycled paper mill. In: 1997 Environmental Conference & Exhibit, Book 1, Minneapolis Convention Center, May 5–7, 1997. Atlanta, GA: TAPPI Press, 461–464.
Wilhelmsson B, Holmstrom M. 1987. Positive formaldehyde-rast after prolonged formaldehyde exposure by inhalation [Abstract]. Lancet 8551:164.
Wilhelmsson B, Holmstrom M. 1992. Possible mechanisms of formaldehyde-induced discomfort in the upper airways. Scand J Work Environ Health 18:403–407.1485166
Wilkins JRIII, Gerken D, Steele L, 1989. Adverse reproductive outcomes among female veterinarians - survey results [Abstract]. J Am Vet Med Assoc 194:1788.
Williams TM, Levine RJ, Blunden P. 1984. Exposure of embalmers to formaldehyde and other chemicals. Am Ind Hyg Assoc J 45:172–176.6720580
*Wilmer JW G, Woutersen RA, Appelman LM, 1987. Subacute (4-week) inhalation toxicity study of formaldehyde in male rats: 8-hour intermittent versus 8-hour continuous exposures. J Appl Toxicol 7:15–16.3611592
*Wilmer JW, Woutersen RA, Appelman LM, 1989. Subchronic (13-week) inhalation toxicity study of formaldehyde in male rats: 8-hour intermittent versus 8-hour continuous exposures. Toxicol Lett 47:287–293.2749773
*Windholz M, Budavari S, Blumetti RF, 1983. The Merck index. 10^th^ ed. Rahway, N.J.: Merck & Co., Inc.
Winters DK, Clejan LA, Cederbaum AI. 1988. Oxidation of glycerol to formaldehyde by rat liver microsomes. Biochem Biophys Res Commun 153:612–617.3382392
*Witek TJ, Schachter EN, Tosun T, 1986. Controlled human studies on the pulmonary effects of indoor air pollution: Experiences with sulfur dioxide and formaldehyde. Environ Int 12:129–135.
*Witek TJ J, Schachter EN, Tosun T, 1987. An evaluation of respiratory effects following exposure to 2.0 ppm formaldehyde in asthmatics: Lung function, symptoms, and airway reactivity. Arch Environ Health 42:230–237.3310924
*Wolf DC, Gross EA, Lyght O, 1995. Immunohistochemical localization of p53, PCNA and TGF-alpha proteins in formaldehyde-induced rat nasal squamous cell carcinomas. Toxicol Appl Pharmacol 132:27–35.7747282
*Wolff GT. 1991. Air pollution. In: Howe-Grant M, ed. Kirk-Othmer Encyclopedia of chemical technology. New York: John Wiley & Sons, Inc., 711–749.
Wolff RK. 1986. Effects of airborne pollutants on mucociliary clearance. Environ Health Perspect 66:223–237.3519203
Wong KL, Stock F, Alarie YC. 1983. Evaluation of the pulmonary toxicity of plasticized polyvinyl chloride thermal decomposition products in guinea pigs by repeated CO_2_ challenges. Toxicol Appl Pharmacol 70:236–248.6414104
Wong O. 1983. An epidemiologic mortality study of a cohort of chemical workers potentially exposed to formaldehyde, with a discussion on SMR and PMR. In: Gibson JE, ed. Formaldehyde toxicity. Washington, DC: Hemisphere Publishing Corporation, 256–272.
*Wood RW, Coleman JB. 1995. Behavioral evaluation of the irritant properties of formaldehyde. Toxicol Appl Pharmacol 130:67–72.7839371
*Woodring JL, Duffy TL, Davis JT, 1985. Measurement of combustion product emission factors of unvented kerosene heaters. Am Ind Hyg Assoc J 46:350–356.3880188
*Woodruff RC, Mason JM, Valencia R, 1985. Chemical mutagenesis testing in Drosophila. V. Results of 53 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:677–702.3930237
*Woodruff TJ, Axelrad DA, Caldwell J, 1998. Public health implications of 1990 Air Toxics concentrations across the United States. Environ Health Perspect 106:245–251.9518474
Wortley P, Vaughan TL, Davis S, 1992. A case-control study of occupational risk factors for laryngeal cancer. Br J Ind Med 49:837–844.1472441
Woskie SR, Smith TJ, Hammond SK, 1988. Estimation of the diesel exhaust exposures of railroad workers: I. Current exposures. Am J Ind Med 13:381–394.3354586
*Woutersen RA, Appleman LM, Wilmer JW, 1987. Subchronic (13-week) inhalation toxicity study of formaldehyde in rats. J Appl Toxicol 7:43–49.3611596
*Wouterson RA, van Garderen-Hoetmer A, Bruijntjes JP, 1989. Nasal tumors in rats after severe injury to the nasal mucosa and prolonged exposure to 10 ppm formaldehyde. J Appl Toxicol 9:39–46.2926095
*Yager JW, Cohn KL, Spear RC, 1986. Sister-chromatid exchanges in lymphocytes of anatomy students exposed to formaldehyde-embalming solution. Mutat Res 174:135–139.3713731
Yamane K, Kobayashi T. 1988. An analysis of the response to formaldehyde in the guinea-pig tracheal smooth muscle [Abstract]. Jpn J Pharmacol 46:161 P.
*Yasuhara A, Shibamoto T. 1995. Quantitative analysis of volatile aldehydes formed from various kinds of fish flesh during heat treatment. J Agric Food Chem 43:94–97.
Ying CJ, Yan WS, Zhao MY, 1997. Micronuclei in nasal mucosa, oral mucosa and lymphocytes in students exposed to formaldehyde vapor in anatomy class. Biomed Environ Sci 10:451–455.9448927
*Zhang J, He Q, Lioy PJ. 1994a. Characteristics of aldehydes: Concentrations, sources, and exposures for indoor and outdoor residential microenvironments. Environ Sci Technol 28:146–152.22175844
*Zhang J, Wilson WE, Lioy PJ. 1994b. Indoor air chemistry: Formation of organic acids and aldehydes. Environ Sci Technol 28:1975–1982.22175941
Zhang R-W, Jiang X-Z. 1988. A preliminary report on the analysis of malignant mortality among anatomists and their assistants. In: Xue S-Z, Liang Y-X, ed. Occupational health in industrialization and modernization. Shanghai: Shanghai Medical University Press, 89–90.
*Zhitkovich A, Costa M. 1992. A simple, sensitive assay to detect DNA-protein crosslinks in intact cells and in vivo. Carcinogenesis 13:1485–1489.1499101
*Ziegler EE, Edwards BB, Jensen RL 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
*Zinn TW, Cline D, Lehmann WF. 1990. Long-term study of formaldehyde emission decay from particleboard. For Prod J 40:15–18.
Zissu D. 1995. Histopathological changes in the respiratory tract of mice exposed to ten families of airborne chemicals. J Appl Toxicol 15:207–213.7560741
*Zwart A, Woutersen RA, Wilmer JWGM, 1988. Cytotoxic and adaptive effects in rat nasal epithelium after 3-day and 13-week exposure to low concentrations of formaldehyde vapour. Toxicology 51:87–99.3413803
*Zweidinger RB, Sigsby JE, Tejada SB, 1988. Detailed hydrocarbon and aldehyde mobile source emissions from roadway studies. Environ Sci Technol 22:956–962.22195719