# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of formaldehyde is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of formaldehyde is located in Table 3-2.

Table 3-1 Chemical Identity of Formaldehyde

Characteristic | Information | Reference
Chemical name | Formaldehyde | Lide and Frederikse 1996
Synonym(s) | Formic aldehyde, methanal, methyl aldehyde, methylene oxide | Budavari et al. 1989
Registered trade name(s)
For 37% aqueous solution^a^ | Formalin, Formol, Moibicid, Veracur | Budavari et al. 1989
For polymeric form^b^ | Paraformaldehyde, Polyoxymethylene, Paraform, Formagene | Budavari et al. 1989
Chemical formula | CH_2_O | Aster 1995
Chemical structure | [image] | Lide and Frederikse 1996
Identification numbers:
CAS Registry | 50-00-0 | Aster 1995
NIOSH RTECS | LP8925000 | HSDB 1995
EPA Hazardous Waste | U122 | HSDB 1995
OHM/TADS | 7216732 | HSDB 1995
DOT/UN/NA/IMCO | CLASS 3/UN1198/IMCO 3.2 | NFPA 1994
HSDB | 164 | HSDB 1999
NCI | No data | HSDB 1999

a Aqueous solutions of formaldehyde available commercially often contain 10–15% methanol to inhibit polymerization.

b Paraformaldehyde is a polymer of formaldehyde and has the formula (CH_2_O)_n_.

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 3-2 Physical and Chemical Properties of Formaldehyde

Property | Information | Reference
Molecular weight | 30.03 | Lide and Frederikse 1996
Color | Colorless | Budavari et al. 1989
Physical state | Gas | Budavari et al. 1989
Melting point | −92 °C | Budavari et al. 1989
Boiling point | −21 °C | ASTER 1996
Density at −20 °C | 0.815 g/mL | Lide and Frederikse 1996
Odor | Pungent, suffocating odor; highly irritating odor | Budavari et al. 1989; NFPA 1994
Odor threshold:
Water | 50 ppm | HSDB 1999
Air | 0.5–1.0 ppm | Klaassen 1996
Taste | 50 ppm | HSDB 1999
Solubility:
Freshwater at 20 °C | Very soluble; up to 55% | Budavari et al. 1989
Saltwater at 25 °C | No data
Organic solvent(s) | Ether, alcohol, acetone, benzene | Lide and Frederikse 1996; Budavari et al. 1989
Partition coefficients:
Log K_ow_ | 0.350 | SRC 1995b
Log K_oc_ | 1.567 | Calculated from Lyman 1982
| No data, negligible | HSDB 1999
Vapor pressure at 25 °C | Gas: vapor pressure>bp; 3,883 mm Hg | HSDB 1999; Howard 1989
Polymerization | Polymerizes; polymerizes readily in water | Budavari et al. 1989
Photolysis | Half-life (in sunlight) 1.6–19 hours producing H_2_ and CO or H^+^ and HCO^−^ | Lewis 1993
Henry’s law constant at 25 °C | 3.27×10^−7^ atm-m^3^/mol | Howard 1989
Autoignition temperature | 300 °C | NFPA 1994
Flashpoint | 60 C | Budavari et al. 1989
Flammability limits at 25 °C | 7–73% | NFPA 1994
Incompatibilities | Reacts with alkalies, acids, and oxidizers | NFPA 1994
Conversion factors (25 °C) | 1 ppb (v/v) = 1.23 μg/m^3^; 1 μg/m^3^ = 0.813 ppb (v/v) | Calculated
Explosive limits | 7–73% | Lewis 1993