# 8 REFERENCES

ACGIH. 2007. Formaldehyde. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 31.
Acheson ED, Barnes HR, Gardner MJ, 1984. Formaldehyde process workers and lung cancer. Lancet 1(8385):1066–1067.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
AIHA. 1988. Formaldehyde. Emergency Response Planning Guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association.
Akbar-Khanzadeh F, Mlynek JS. 1997. Changes in respiratory function after one and three hours of exposure to formaldehyde in non-smoking subjects. Occup Environ Med 24:296–300.
Akbar-Khanzadeh F, Vaquerano MU, Akbar-Khanzadeh M, 1994. Formaldehyde exposure, acute pulmonary response, and exposure control options in a gross anatomy laboratory. Am J Ind Med 26:61– 75.8074125
Alexandersson R, Hedenstierna G. 1988. Respiratory hazards associated with exposure to formaldehyde and solvents in acid-curing paints. Arch Environ Health 43:222–227.3260092
Alexandersson R, Hedenstierna G. 1989. Pulmonary function in wood workers exposed to formaldehyde: A prospective study. Arch Environ Health 44:5–11.2916856
Anderson B, Tan T, Marks J. 2007. Patch-test reactions to formaldehyde, bioban and other formaldehyde releasers. Dermatitis 18(2):92–95.17498414
Andjelkovich DA, Janszen DB, Brown MH, 1995. Mortality of iron foundry workers: IV. Analysis of a subcohort exposed to formaldehyde. J Occup Environ Med 37:826–837.7552467
Andjelkovich DA, Shy CM, Brown MH, 1994. Mortality of iron foundry workers. III. Lung cancer case-control study. J Occup Med 36:1301–1308.7884571
Armstrong R, Imrey P, Lye M, 2000. Nasopharyngeal carcinoma in Malaysian Chinese: Occupational exposures to particles, formaldehyde and heat. Int J Epidemiol 29(6):991–998.11101539
Arts J, de Heer C, Woutersen R. 2006a. Local effects in the respiratory tract: Relevance of subjectively measured irritation for setting occupational exposure limits. Int Arch Occup Environ Health 79(4):283–– 298.16283365
Arts JH, Rennen MA, deHeer C. 2006b. Inhaled formaldehyde: Evaluation of sensory irritation in relation to carcinogenicity. Regul Toxicol Pharmacol 44 (2):144–160.16413643
Aslan H, Songur A, Tunc T, 2006. Effects of formaldehyde exposure on granule cell number and volume of dentate gyrus: A histopathological and sterological study. Brain Res 1122(1):191–200.17011527
Atkinson R, Arey J. 2003. Atmospheric degradation of volatile organic compounds. Chem Rev 103:4605–4638.14664626
Austin J. 2003. Day-of-week patterns in toxic air contaminants in southern California. J Air Waste Manage Assoc 53:889–896.
Ayaki H, Lee MJ, Sumino K, 2005. Different cytoprotective effects of antioxidants and change in the iron regulatory system in rodent cells exposed to paraquat or formaldehyde. Toxicology 208(1):73–– 79.15664434
Baccioglu A, Kalpaklioglu A. 2007. An unusual form of formaldehyde-induced lung disease. Allergol Immunopathol (Madr) 35(3):110–112.17594875
Bach Bodil, Pedersen Ole Find, and Mohvave Lars, 1990. Human Performance During Experimental Formaldehyde Exposure, Environmental International, Vol. 16 pp. 105–113.
Ballarin C, Sarto F, Giacomelli L, 1992. Micronucleated cells in nasal mucosa of formaldehyde-exposed workers. Mutat Res 280:1–7.1377340
Bertazzi PA, Pesatori A, Guercilena S, 1989. Rischio cancerogeno per i produttori di resine esposti a formaldeide: Estensione del follow-up. Med Lav 80:111–122.2770616
Bertazzi PA, Pesatori AC, Radice L, 1986. Exposure to formaldehyde and cancer mortality in a cohort of workers producing resins. Scand J Work Environ Health 12:461–468.3787218
Blair A, Saracci R, Stewart PA, 1990. Epidemiologic evidence on the relationship between formaldehyde exposure and cancer. Scand J Work Environ Health 16:381–393.2284588
Blair A, Stewart P, O'Berg M, 1986. Mortality among industrial workers exposed to formaldehyde. J Natl Cancer Inst 76:1071–1084.3458945
Bolt HM. 1987. Experimental toxicology of formaldehyde. J Cancer Res Clin Oncol 113:305–309.3298280
Bono R, Vincenti M, Schiliro T, 2006. N-methylenvaline in a group of subjects occupationally exposed to formaldehyde. Toxicol Lett 161(1):10–17.16153790
Bosetti C, McLaughlin JK, Tarone RE, 2008. Formaldehyde and cancer risk: A quantitative review of cohort studies through 2006. Ann Oncol 19:29–43.17897961
Boysen M, Zadig E, Digernes V, 1990. Nasal mucosa in workers exposed to formaldehyde: A pilot study. Br J Ind Med 47:116–121.2310715
Bracken MJ, Leasa DJ, Morgan WK C. 1985. Exposure to formaldehyde: Relationship to respiratory symptoms and function. Can J Public Health 76:312–316.4084884
Brown SK, Mahoney KJ, Cheng M. 2004. Room chamber assessment of the pollutant emission properties of (nominally) low-emission unflued gas heaters. Indoor Air 14:84–91.15663463
Burgaz S, Cakmak G, Erdem O, 2001. Micronuclei frequencies in exfoliated nasal mucosa cells from pathology and anatomy laboratory workers exposed to formaldehyde. Neoplasma 48(2):144–147.11478696
Burgaz S, Erdem O, Cakmak G, 2002. Cytogenetic analysis of buccal cells from shoe-workers and pathology and anatomy laboratory workers exposed to n-hexane, toluene, methyl ethyl ketone and formaldehyde. (Erratum in: Biomarkers 11(4): 383). Biomarkers 7(2):151–161.12101634
C&EN. 1989. Formaldehyde. Chem Mark Rep. September 18, 1989, 54.
C&EN. 1994. Production by the U.S. chemical industry: Growth continues in chemical production. Chem Eng News 72:30–36.
C&EN. 1995. Formaldehyde. Chem Mark Rep September 11, 1995, 39.
C&EN. 1998. Formaldehyde. Chem Mark Rep June 22, 1998, 49.
Caraccio TR, McGuigan MA. 2004. Formaldehyde and glutaraldehyde. In: Dart RC, ed. Medical toxicology. Philadelphia, PA: Lippincott Williams & Wilkins, 1246–1250.
Casanova M, Heck Hd'A. 1987. Further studies of the metabolic incorporation and covalent binding of inhaled [^3^H]- and [^14^C] formaldehyde in Fischer-344 rats: Effects of glutathione depletion. Toxicol Appl Pharmacol 89:105–121.2438809
Casanova M, Morgan KT, Gross EA, 1994. DNA-protein cross-links and cell replication at specific sites in the nose of F344 rats exposed subchronically to formaldehyde. Fundam Appl Toxicol 23:525– 536.7867904
Casanova M, Morgan KT, Steinhagen WH, 1991. Covalent binding of inhaled formaldehyde to DNA in the respiratory tract of Rhesus monkeys: Pharmacokinetics, rat-to-monkey interspecies scaling, and extrapolation to man. Fundam Appl Toxicol 17:409–428.1765228
Casanova-Schmitz M, Raymond MD, Heck Hd'A. 1984b. Oxidation of formaldehyde and acetaldehyde by NAD+-dependent dehydrogenases in rat nasal mucosal homogenates. Biochem Pharmacol 33:1137– 1142.6477684
Casanova-Schmitz M, Starr TB, Heck Hd'A. 1984a. Differentiation between metabolic incorporation and covalent binding in the labeling of macromolecules in the rat nasal mucosa and bone marrow by inhaled [^14^C]- and [^3^H] formaldehyde. Toxicol Appl Pharmacol 76:26–44.6207627
Casset A, Marchand C, Purohit, 2006. Inhaled formaldehyde exposure: Effect on bronchial response to mite allergen in sensitized asthma patients. Allergy 61(11):1344–1350.17002712
CDC. 2008. Interim findings on formaldehyde levels in FEMA-supplied travel trailers, park models, and mobile homes. Atlanta, GA: Centers for Disease Control and Prevention.
Chang JC F, Gross EA, Swenberg JA, 1983. Nasal cavity deposition, histopathology, and cell proliferation after single or repeated formaldehyde exposure in B6C3F1 mice and F-344 rats. Toxicol Appl Pharmacol 68:161–176.6857658
Charpin D, Dutau H, Falzon S. 2000. Hypersensitivity to formaldehyde. Allergy 55(10):986–987.11030391
CIIT (1999). Formaldehyde: Hazard characterization and dose-response assessment for carcinogenicity by route of inhalation. Report, Chemical Industry Institute of Toxicology, Research Triangle Park, North Carolina.
CMR. 2001. Chemical profile: Formaldehyde. Chem Market Rep.
CMR. 2007. Chemical profile: Formaldehyde. Chem Market Rep, 34.
Coggon D, Harris EC, Poole J, 2003. Extended follow-up of a cohort of British chemical workers exposed to formaldehyde. (Comment in: J Natl Cancer Inst 96(13):1037, author reply 1037–1038). J Natl Cancer Inst 95(21):1608–1615.14600093
Cohen Hubal EA, Schlosser PM, Conolly RB, 1997. Comparison of inhaled formaldehyde dosimetry predictions with DNA-protein cross-link measurements in the rat nasal passages. Toxicol Appl Pharmacol 143:47–55.9073591
Cole P, Axten C. 2004. Formaldehyde and leukemia: An improbable causal relationship. Regul Toxicol Pharmacol 40(2):107–112.15450714
Collins JJ, Lineker GA. 2004. A review and meta-analysis of formaldehyde exposure and leukemia. Regul Toxicol Pharmacol 40:81–91.15450712
Collins JJ, Acquavella JF, Esmen NA. 1997. An updated meta-analysis of formaldehyde exposure and upper respiratory tract cancers. J Occup Environ Med 39:639–651.9253725
Collins JJ, Ness R, Tyl RW, 2001. A review of adverse pregnancy outcomes and formaldehyde exposure in human and animal studies. Regul Toxicol Pharmacol 34:17–34.11502153
Connor TH, Ward JB, Legator MS. 1985b. Absence of mutagenicity in the urine of autopsy service workers exposed to formaldehyde: Factors influencing mutagenicity testing of urine. Int Arch Occup Environ Health 56:225–237.4066051
Conolly RB, Andersen ME. 1993. An approach to mechanism-based cancer risk assessment for formaldehyde. Environ Health Perspect Suppl 101:169–176.
Conolly RB, Kimbell JS, Janszen DB, 2002. Dose response for formaldehyde-induced cytotoxicity in the human respiratory tract. Regul Toxicol Pharmacol 35:32–43.11846634
Conolly RB, Kimbell JS, Janszen D, 2003. Biologically motivated computational modeling of formaldehyde carcinogenicity in the F344 rat. Toxicol Sci 75(2):432–437.12857938
Conolly RB, Kimbell JS, Janszen D, 2004. Human respiratory tract cancer risks of inhaled formaldehyde: Dose-response predictions derived from biologically-motivated computational modeling of a combined rodent and human dataset. Toxicol Sci 82(1):279–296.15254341
Conolly RB, Lilly PD, Kimbell JS. 2000. Simulation modeling of the tissue disposition of formaldehyde to predict nasal DNA-protein cross-links in Fischer 344 rats, rhesus monkeys, and humans. Environ Health Perspect Suppl 108:919–924.
Conolly RB, Miller FJ, Kimbell JS, 2009. Formaldehyde risk assessment. Ann Hyg 53:181–184.
Conolly RB, Morgan KT, Andersen ME, 1992. A biologically-based risk assessment strategy for inhaled formaldehyde. Comments Toxicol 4:269–293.
Cooke CM, Bailey NJ, Shaw G, 2003. Interaction of formaldehyde with soil humic substances: Separation by GFC and characterization by 1H-NMR spectroscopy. Bull Environ Contam Toxicol 70:761–768.12677388
Cowan J, Abu-Daabes M, Banerjee S. 2005. Controlling formaldehyde emissions with boiler ash. Environ Sci Technol 39(13):5101–5104.16053116
CRISP. 2008. Formaldehyde. Computer Retrieval of Information on Scientific Projects Database. Bethesda, MD: National Institutes of Health. http://crisp.cit.nih.gov/. April 24, 2008.
Crump KS, Chen C, Fox JF, 2008. Sensitivity analysis of biologically motivated model for formaldehyde-induced respiratory cancer in humans. Ann Occup Hyg 52:181–184.
Dallas CE, Scott MJ, Ward JB Jr, 1992. Cytogenetic analysis of pulmonary lavage and bone marrow cells of rats after repeated formaldehyde inhalation. J Appl Toxicol 12:199–203.1378462
Dasgupta PK, Li J, Zhang G, 2005. A summertime ambient formaldehyde in five U.S. metropolitan areas: Nashville, Atlanta, Houston, Philadelphia, and Tampa. Environ Sci Technol 39(13):4767–4783.16053074
Dearman RJ, Basketter DA, Evans P, 1999. Comparison of cytokine secretion profiles provoked in mice by glutaraldehyde and formaldehyde. Clin Exp Allergy 29(1):124–132.10051711
Delfino RJ, Gong H, Linn WS, 2003. Asthma symptoms in Hispanic children and daily ambient exposures to toxic and criteria air pollutants. Environ Health Perspect 111(4):647–656.12676630
de Serres F, Brockman H. 1999. Comparison of the spectra of genetic damage in formaldehyde-induced ad-3 mutations between DNA repair-proficient and -deficient heterokaryons of Neurospora crassa. Mutat Res 437(2):151–163.10556619
DOE. 2003. Volatile organic chemical emissions from structural insulated panel (SIP) materials and implications for indoor air quality. Washington, DC: U.S. Department of Energy. DE2003816228. http://repositories.cdlib.org/cgi/viewcontent.cgi?article=1434&context=lbnl. May 01, 2008.
DOE. 2004. Volatile organic compound concentrations and emission rates measured over one year in a new manufactured house. Washington, DC: U.S. Department of Energy. DE2005838617. http://www.osti.gov/bridge/servlets/purl/838617-FClh9l/native/. May 01, 2008.
Doi S, Suzuki S, Morishita M, 2003. The prevalence of IgE sensitization to formaldehyde in asthmatic children. Allergy 58:668–671.12823129
Duhayon S, Hoet P, Van Maele-Fabry G, 2008. Carcinogenic potential of formaldehyde in occupational settings; a critical assessment and possible impact on occupational exposure levels. Int Arch Occup Environ Health 81(6):695–710.17955258
Dykewicz MS, Patterson R, Cugell DW, 1991. Serum IgE and IgG to formaldehyde-human serum albumin: Lack of relation to gaseous formaldehyde exposure and symptoms. J Allergy Clin Immunol 87:48–57.1991923
Edling C, Hellquist H, Odkvist L. 1988. Occupational exposure to formaldehyde and histopathological changes in the nasal mucosa. Br J Ind Med 45:761–765.3203081
Eiroa M, Kennes C, Veiga M. 2005. Simultaneous nitrification and formaldehyde biodegradation in an activated sludge unit. Bioresour Technol 96(17):1914–1918.16084371
Emri G, Schaefer D, Held B, 2004. Low concentrations of formaldehyde induce DNA damage and delay DNA repair after UV irradiation in human skin cells. Exp Dermatol 13(5):305–315.15140021
Environment Canada/Health Canada. 2001. Canadian Environmental Protection Act, 1999. Priority substances list assessment report. Formaldehyde. Government of Canada. Environment Canada. Health Canada.
EPA. 1991. Formaldehyde risk assessment update—final draft. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
EPA. 1999. National air toxics program: The integrated urban strategy. U.S. Environmental Protection Agency. Fed Regist 64 FR 38706. http://www.gpoaccess.gov/fr/index.html. May 14, 2008.
EPA. 2003. National primary drinking water standards. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F03016. http://www.epa.gov/safewater/mcl.html. March 07, 2006.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006a. 2006 Edition of the drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822R06013. http://www.epa.gov/waterscience/criteria/drinking/dwstandards.pdf. April 11, 2007.
EPA. 2006b. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 08, 2008.
EPA. 2007a. Acute exposure guideline levels (AEGLs). Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/pubs/compiled.pdf. April 24, 2008.
EPA. 2007b. The Clean Air Act amendments of 1990 list of hazardous air pollutants. Clean Air Act. United States Code 42 USC 7412. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/atw/orig189.html. April 24, 2008.
EPA. 2008a. Acute exposure guideline levels (AEGLs). Second AEGL chemical priority list. U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/pubs/priority_2.htm. April 24, 2008.
EPA. 2008b. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. 2008c. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. 2008d. Determination of reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. 2008e. List of chemicals produced by affected facilities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68.489.
EPA. 2008f. The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. 2008g. List of substances. U.S. Environmental Protection Agency. Code of Federal Regulations.40 CFR 68.130. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. 2008h. Master testing list. Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. http://www.epa.gov/opptintr/chemtest/pubs/mtl.htm. April 24, 2008.
EPA. 2008i. Table 2 to subpart F of part 63—organic hazardous air pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68.107, Table 2.
EPA. 2008j. Toxic chemical release reporting. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/lawsregs/search/40cfr.html. April 24, 2008.
EPA. 2008k. Appendix VIII to part 261—Hazardous constituents. U.S. Environmental Protection Agency. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=c3def368984683884963552af39feee3&rgn=div9&view=text&node=40:25.0.1.1.2.5.1.5. 9&idno=40. May 21, 2008.
Ezratty V, Bonay M, Neukirch C, 2007. Effect of formaldehyde on asthmatic response to inhaled allergen challenge. Environ Health Perspect 115(2):210–214.17384766
Fazeli S, Davarian A, Azarhoush R, 2006. Histopathologic changes of rat liver following formaldehyde exposure. Pak J Biol Sci 9(11):2137–2140.
FDA. 2007a. Food additives permitted in feed and drinking water of animals. Code of Federal Regulations. 21 CFR 573.460. U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. May 14, 2008.
FDA. 2007b. Indirect food additives: Adhesives and components of coatings. Code of Federal Regulations. 21 CFR 175.105. U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm. April 24, 2008.
FDA. 2008. EAFUS: A food additive database. U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms/eafus.html. April 24, 2008.
FEDRIP. 2008. Formaldehyde. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Feick P, Haas S, Singer M, 2006. Low-dose exposure of intestinal epithelial cells to formaldehyde results in MAP kinase activation and molecular alteration of the focal adhesion protein paxillin. Toxicology 219(1–3):60–72.16352387
Fennell TR. 1994. Development of methods for measuring biological markers of formaldehyde exposure. Res Rep Health Eff Inst 67:1–26.
Franco AL, Damazo AS, de Souza HR, 2006. Pulmonary neutrophil recruitment and bronchial reactivity in formaldehyde-exposed rats are modulated by mast cells and differentially by neuropeptides and nitric oxide. Toxicol Appl Pharmacol 214:35–42.16427670
Franklin P, Dingle P, Stick S. 2000. Raised exhaled nitric oxide in healthy children is associated with domestic formaldehyde levels. Am J Respir Crit Care Med 161(5):1757–1759.10806184
Franks SJ. 2005. A mathematical model for the absorption and metabolism of formaldehyde vapour by humans. Toxicol Appl Pharmacol 206(3):309–320.16039942
Fransman W, McLean D, Douwes J, 2003. Respiratory symptoms and occupational exposures in New Zealand plywood mill workers. Ann Occup Hyg 47(4):287–295.12765869
Beane Freeman L, Blair A, Lubin J, Stewart P, Hayes R, Hoover R, Hauptmann M, 2009a. Mortality from lymphohematopoietic malignancies among workers in formaldehyde industries: the National Cancer Institute report. J. Natl. Cancer Institute 101:751–761.
Frenzilli G, Bosco E, Barale R. 2000. Validation of single cell gel assay in human leukocytes with 18 reference compounds. Mutat Res 468(2):93–108.10882888
Fujii K, Tsuji K, Matsuura H, 2005. Effect of formaldehyde gas exposure in a murine allergic contact hypersensitivity model. Immunopharmacol Immunotoxicol 27(1):163–175.15803868
Fujimaki H, Kurokawa Y, Kakeyama M, 2004. Inhalation of low-level formaldehyde enhances nerve growth factor production in the hippocampus of mice. Neuroimmunomodulation 11(6):373–375.15467352
Fujimaki H, Kurokawa Y, Kunugita N, 2005. Differential immunogenic and neurogenic inflammatory responses in an allergic mouse model exposed to low levels of formaldehyde. (Erratum to: Toxicology 197(1):1–13). Toxicology 209(3):305.
Gammage RB, Hawthorne AR. 1985. Current status of measurement techniques and concentrations of formaldehyde in residences. In: Jacobs VA, ed. Indoor air and human health. New York, NY: Lewis Publishers, Inc., 117–130.
Gardner MJ, Pannett B, Winter PD, 1993. A cohort study of workers exposed to formaldehyde in the British chemical industry: An update. Br J Ind Med 50:827–834.8398877
Garrett M, Hooper M, Hooper B, 1999. Increased risk of allergy in children due to formaldehyde exposure in homes. Allergy 54(4):330–337.10371091
Garrigos MC, Reche F, Jimenez A. 2001. Potentially toxic colorant precursors and preservatives used in finger paints. Bull Environ Contam Toxicol 66:557–562.11443323
Gaylor DW, Lutz WK, Conolly RB. 2004. Statistical analysis of nonmonotonic dose-response relationships: Research design and analysis of nasal cell proliferation in rats exposed to formaldehyde. (Comment in: Toxicol Sci 92(1):346). Toxicol Sci 77(1):158–164.14600280
Georgieva A, Kimbell J, Schlosser P. 2003. A distributed-parameter model for formaldehyde uptake and disposition in the rat nasal lining. (Erratum in: Inhal Toxicol 16(4):245). Inhal Toxicol 15(14):1435– 1463.14648358
Gerberich HR, Seaman GC. 1994. Formaldehyde. In: Kirk-Othmer encyclopedia of chemical technology. 4th ed. New York, NY: John Wiley & Sons, V11: 929–951.
Gerberich HR, Seaman GC. 2004. Formaldehyde. Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, 107–128.
Gerberich HR, Stautzenberger AL, Hopkins WC. 1980. Formaldehyde. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, 231–250.
Golden R, Pyatt D, Shields P. 2006. Formaldehyde as a potential human leukemogen: An assessment of biological plausibility. Crit Rev Toxicol 36(2):135–153.16736940
Goldfrank LR, Flomenbaum NE, Lewin NA, , eds. 2002. Formaldehyde. In: Goldfrank's toxicologic emergencies. New York, NY: McGraw-Hill, 1284.
Gordon SY, Callahan PJ, Nishioka MG, 1999. Residential environmental measurements in the national human exposure assessment survey (NHEXAS) pilot study in Arizona: Preliminary results for pesticides and VOCs. J Expo Anal Environ Epidemiol 9(5):456–470.10554148
Grammer LC, Harris KE, Shaughnessy MA, 1990. Clinical and immunologic evaluation of 37 workers exposed to gaseous formaldehyde. J Allergy Clin Immunol 86:177–181.2384647
Gulec M, Gurel A, Armutcu F. 2006a. Vitamin E protects against oxidative damage caused by formaldehyde in the liver and plasma of rats. Mol Cell Biochem 290(1–2):61–67.16937016
Gulec M, Songur A, Sahin S, 2006b. Antioxidant enzyme activities and lipid peroxidation products in heart tissue of subacute and subchronic formaldehyde-exposed rats: A preliminary study. Toxicol Ind Health 22(3):117–124.16716041
Gurel A, Coskun O, Armutcu F, 2005. Vitamin E against oxidative damage caused by formaldehyde in frontal cortex and hippocampus: Biochemical and histological studies. J Chem Neuroanat 29(3):173–178.15820619
Hansch C, Leo A, Hoekman D. 1995. In: Heller SR, ed. Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington DC: American Chemical Society, 3.
Hauptmann M, Lubin JH, Stewart PA, 2003. Mortality from lymphohematopoietic malignancies among workers in formaldehyde industries. (Comment in: J Natl Cancer Inst 96(12):966–967, author reply 967–968). J Natl Cancer Inst 95(21):1615–1623.14600094
Hauptmann M, Lubin JH, Stewart PA, 2004. Mortality from solid cancers among workers in formaldehyde industries. (Comment in: Am J Epidemiol 161(11):1089–1090; author reply 1090–1091). Am J Epidemiol 159(12):1117–1130.15191929
Hauptmann M, Stewart PA, Lubin JH, 2009. Morality from lymphohematopoietic malignancies and brain cancer among embalmers exposedd to formaldehyde. J Natl Cancer Inst 101:1696–1708.19933446
Hawthorne AR, Gammage RB, Dudney CS. 1986. An indoor air quality study of 40 East Tennessee homes. Environ Int 12:221–239.
Hayashi T, Reece CA, Shibamoto T. 1986. Gas chromatographic determination of formaldehyde in coffee via thiazolidine derivative. J Assoc Off Anal Chem 69:101–105.3949681
HazDat. 2008. Formaldehyde. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. May 2, 2008.
Heck Hd’A, Casanova M. 2004. The implausibility of leukemia induction by formaldehyde: A critical review of the biological evidence on distant-site toxicity. Regul Toxicol Pharmacol 40(2):92–106.15450713
Heck Hd'A, Casanova M, Starr TB. 1990. Formaldehyde toxicity-new understanding. CRC Crit Rev Toxicol 20:397–426.
Hernandez 1994. Risk assessment of formaldehyde. J Hazard Mater 39:161–172.
Hester S, Barry W, Zou F, 2005. Transcriptomic analysis of F344 rat nasal epithelium suggests that the lack of carcinogenic response to glutaraldehyde is due to its greater toxicity compared to formaldehyde. Toxicol Pathol 33(4):415–424.16036858
Hester S, Benavides G, Yoon L, 2003. Formaldehyde-induced gene expression in F344 rat nasal respiratory epithelium. Toxicology 187(1):13–24.12679049
Hildesheim A, Dosemeci M, Chan C. 2001. Occupational exposure to wood, formaldehyde, and solvents and risk of nasopharyngeal carcinoma. Cancer Epidemiol Biomarkers Prev 10(11):1145–1153.11700262
Hilton J, Dearman RJ, Basketter DA, 1996. Experimental assessment of the sensitizing properties of formaldehyde. Food Chem Toxicol 34:571–578.8690318
Hodgson AT, Beal D, Chandra S. 1999. Concentrations and sources of formaldehyde and volatile organic compounds in four new manufactured houses. In: Indoor Air 99, Proceedings of the 8th International Conference on Indoor Air Quality and Climate. Edinburgh, Scotland. August 8–13, 1999, vol. 4. Construction Research Communications Ltd. London, EC1R 4GB, UK; pp. 119–124.
Hodgson AT, Rudd AF, Beal D, 2000. Volatile organic compound concentrations and emission rates in new manufactures and site-built houses. Indoor Air 10:178–192.10979199
Holmstrom M, Wihelmsson B. 1988. Respiratory symptoms and pathophysiological effects of occupational exposure to formaldehyde and wood dust. Scand J Work Environ Health 14:306–311.3201190
Holmstrom M, Wilhelmsson B, Hellquist H, 1989. Histological changes in the nasal mucosa in persons occupationally exposed to formaldehyde alone and in combination with wood dust. Acta Otolaryngol (Stockh) 107:120–129.2929309
Holness DL, Nethercott JR. 1989. Health status of funeral service workers exposed to formaldehyde. Arch Environ Health 44:222–228.2528945
Horvath EP, Anderson H, Pierce WE, 1988. Effects of formaldehyde on the mucous membranes and lungs: A study of an industrial population. JAMA 259:701–707.3336189
IARC. 1995. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Vol. 62: Wood dusts and formaldehyde. Lyon, France: International Agency for Research on Cancer, 217– 362.
IARC. 2006. IARC monographs on the evaluation of carcinogenic risks to humans. Vol. 88. Formaldehyde, 2-butoxyethanol and 1-tert-butoxypropan-2-ol. Geneva, Switzerland: International Agency for Research on Cancer, 39–93, 273.
IARC. 2008. Agents reviewed by the IARC monographs: Volumes 1–99. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. April 24, 2008.
IARC. 2009. A review of human carcinogens—Part F: Chemical agents and related occupations. International Agency for Research on Cancer. http://monographs.iarc.fr/pdfnews/WG-100F.pdf. May 17, 2010.
Iarmarcovai G, Bonassi S, Sari-Minodier I. 2007. Exposure to genotoxic agents, host factors, and lifestyle influence the number of centromeric signals in micronuclei: A pooled re-analysis. Mutat Res 615(2–1):18–27.17198715
Im H, Oh E, Mun J, 2006. Evaluation of toxicological monitoring markers using proteomic analysis in rats exposed to formaldehyde. J Proteome Res 5(10):2523–2524.17022622
IRIS. 2010. Formaldehyde. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=223614 . July 15, 2010.
Jaakkola JJ, Parise H, Kislitsin V, 2004. Asthma, wheezing, and allergies in Russian schoolchildren in relation to new surface materials in the home. Am J Public Health 94:560–562.15054004
Jung W, Kim E, Lee E, 2007. Formaldehyde exposure induces airway inflammation by increasing eosinophil infiltrations through the regulation of reactive oxygen species production. Environ Toxicol Pharmacol 24(2):174–182.21783807
Kamata E, Nakadate M, Uchida O, 1997. Results of a 28-month chronic inhalation toxicity study of formaldehyde in male Fischer-344 rats. J Toxicol Sci 22:239–254.
Kaminski J, Atwal AS, Mahadevan S. 1993. Determination of formaldehyde in fresh and retail milk by liquid column chromatography. J Assoc Off Anal Chem 76:1010–1013.
Kepler GM, Richardson RB, Morgan KT, 1998. Computer simulation of inspiratory nasal airflow and inhaled gas uptake in a Rhesus monkey. Toxicol Appl Pharmacol 150:1–11.9630447
Kerns WD, Pavkov KL, Donofrio DJ, 1983. Carcinogenicity of formaldehyde in rats and mice after long-term inhalation exposure. Cancer Res 43:4382–4391.6871871
Khamgaonkar MB, Fulare MB. 1991. Pulmonary effects of formaldehyde exposure—an environmental-epidemiological study. Indian J Chest Dis Allied Sci 33:9–13.1791022
Kiec-Swierczynska M. 1996. Occupational allergic contact dermatitis in Lodz: 1990–1994. Occup Med 48:205–208.
Kim C, Song J, Ahn Y, 2001. Occupational asthma due to formaldehyde. Yonsei Med J 42(4):440–445.11519088
Kim H, Kim Y, Cho S. 1999. Formaldehyde exposure levels and serum antibodies to formaldehyde-human serum albumin of Korean medical students. Arch Environ Health 54(2):115–118.10094289
Kimbell JS. 2006. Nasal dosimetry of inhaled gases and particles: Where do inhaled agents go in the nose? Toxicol Pathol 34(3):270–273.16698725
Kimbell JS, Subramaniam RP. 2001. Use of computational fluid dynamics for dosimetry of inhaled gases in the nasal passages. Inhal Toxicol 13(5):325–334.11295865
Kimbell JS, Gross EA, Richardson RB, 1997a. Correlation of regional formaldehyde flux predictions with the distribution of formaldehyde-induced squamous metaplasia in F344 rat nasal passages. Mutat Res 380:143–154.9385395
Kimbell JS, Overton JH, Subramaniam RP, 2001a. Dosimetry modeling of inhaled formaldehyde: Binning nasal flux predictions for quantitative risk assessment. Toxicol Sci 64(1):111–121.11606807
Kimbell JS, Subramaniam RP, Gross EA, 2001b. Dosimetry modeling of inhaled formaldehyde: Comparisons of local flux predictions in the rat, monkey, and human nasal passages. Toxicol Sci 64(1):100–110.11606806
Kimbell JS, Subramaniam RP, Miller FJ. 1997b. Computer models of nasal airflow inhaled gas uptake in the rat, monkey, and human: Implications for interspecies dosimetry. CIIT Act 17:1–12.
Kitaev EM, Savchenko VA, Lovchikov VV, 1984, Embryonic development and some indices of reproductive function in rats after inhalation exposure to formaldhyde before impregnation, Akush. Ginekol (Mosk.), No. 10, pp. 49–52.
Krakowiak A, Gorski P, Pazdrak K, 1998. Airway response to formaldehyde inhalation in asthmatic subjects with suspected respiratory formaldehyde sensitization. Am J Ind Med 33:274–281.9481426
Kriebel D, Myers D, Cheng M, 2001. Short term effects of formaldehyde on peak expiratory flow and irritant symptoms. Arch Environ Health 56(1):11–18.11256851
Kriebel D, Sama SR, Cocanour B. 1993. Reversible pulmonary responses to formaldehyde: A study of clinical anatomy students. Am Rev Respir Dis 148:1509–1515.8256892
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. New York, NY: Raven Press, Ltd., 149–188.
Krzyzanowski M, Quackenboss JJ, Lebowitz MD. 1990. Chronic respiratory effects of indoor formaldehyde exposure. Environ Res 52:117–125.2394203
Kulle TJ. 1993. Acute odor and irritation response in health nonsmokers with formaldehyde exposure. Inhal Toxicol 5:323–332.
Kulle TJ, Sauder LR, Hebel JR, 1987. Formaldehyde dose-response in healthy nonsmokers. J Air Pollut Control Assoc 37:919–924.
Kum C, Kiral F, Sekkin S, 2007. Effects of xylene and formaldehyde inhalations on oxidative stress in adult and developing rats livers. Exp Anim 56(1):35–42.17283889
Kuykendall JR, Trela BA, Bogdanffy MS. 1995. DNA-protein crosslink formation in rat nasal epithelial cells by hexamethylphosphoramide and its correlation with formaldehyde production. Mutat Res 343:209–218.7623875
Lang I, Bruckner T, Triebig G. 2008. Formaldehyde and chemosensory irritation in humans: A controlled human exposure study. Regul Toxicol Pharmacol 50:23–36.17942205
Lee M, Kim Y, Na T, 2008. Identification of formaldehyde-responsive genes by suppression subtractive hybridization. Toxicology 243(1–2):224–235.18045764
Leikin JB, Paloucek JB. 2002. Formaldehyde. In: Leikin and Paloucek's poisoning and toxicology handbook. Hudson, OH: Lexi-Comp, Inc, 600–602.
Lemiere C, Desjardins A, Cloutier Y, 1995. Occupational asthma due to formaldehyde resin dust with and without reaction to formaldehyde gas. Eur Resp J 8:861–865.
Leonardos G, Kendall D, Barnard N. 1969. Odor threshold determinations of 53 odorant chemicals. J Air Pollut Control Assoc 19:91–95.
Li G, Lee H, Shin H, 2007. Identification of gene markers for formaldehyde exposure in humans. Environ Health Perspect 115(10):1460–1466.17938736
Lu Z, Li CM, Qiao Y, 2008. Effect of inhaled formaldehyde on learning and memory of mice. Indoor Air 18:77–83.18333987
Luce D, Leclerc A, Begin D, 2002. Sinonasal cancer and occupational exposures: A polled analysis of 12 case-control studies. Cancer Causes Control 13:147–157.11936821
Lyapina M, Zhelezova G, Petrova E, 2004. Flow cytometric determination of neutrophil respiratory burst activity in workers exposed to formaldehyde. Int Arch Occup Environ Health 77(5):335–340.15127208
Malaka T, Kodama AM. 1990. Respiratory health of plywood workers occupationally exposed to formaldehyde. Arch Environ Health 45:288–294.2256713
Malek F, Moritz K, Fanghanel J. 2003a. Formaldehyde inhalation & open field behaviour in rats. Indian J Med Res 118:90–96.14680205
Malek F, Moritz K, Fanghanel J. 2003b. A study on specific behavioral effects of formaldehyde in the rat. J Exp Anim Sci 42(3):160–170.
Malek F, Moritz K, Fanghanel J. 2003c. A study on the effect of inhalative formaldehyde exposure on water labyrinth test performance in rats. Ann Anat 185(3):277–285.12801093
Malek F, Moritz K, Fanghanel J. 2004. Effects of a single inhalative exposure to formaldehyde on the open field behavior of mice. Int J Hyg Environ Health 207(2):151–158.15031957
Mansfield CT, Hodge BT, Hege RB, 1977. Analysis of formaldehyde in tobacco smoke by high performance liquid chromatography. J Chromatogr Sci 15:301–302.561117
Marks JG J, Belsito DV, DeLeo VA, 1995. North American contact dermatitis group standard tray patch test results (1992 to 1994). Am J Contact Dermatitis 6:160–165.
Maronpot RR, Miller RA, Clarke WJ, 1986. Toxicity of formaldehyde vapor in B6C3F1 mice exposed for 13 weeks. Toxicology 41:253–266.3775776
Maroziene L, Grazuleviciene R. 2002. Maternal exposure to low-level air pollution and pregnancy outcomes: A population-based study. Environ Health 1(1):6.12495448
Marsh GM, Youk AO. 2004. Reevaluation of mortality risks from leukemia in the formaldehyde cohort study of the National Cancer Institute. Regul Toxicol Pharmacol 40(2):113–124.15450715
Marsh GM, Youk AO. 2005. Reevaluation of mortality risks from nasopharyngeal cancer in the formaldehyde cohort study of the National Cancer Institute. Regul Toxicol Pharmacol 42(3):275–283.15978711
Marsh GM, Buchanich JM, Youk AO. 2001. Historical cohort study of US man-made vitreous fiber production workers: VI. Respiratory system cancer standardized mortality ratios adjusted for the confounding effect of cigarette smoking. J Occup Environ Med 43(9):803–808.11561363
Marsh GM, Stone RA, Esmen NA, 1994. Mortality patterns among chemical plant workers exposed to formaldehyde and other substances. J Natl Cancer Inst 86:384–386.8308930
Marsh GM, Stone RA, Esmen NA, 1996. Mortality among chemical workers in a factory where formaldehyde was used. Occup Environ Med 53:613–627.8882119
Marsh GM, Youk AO, Buchanich JM, 2002. Pharyngeal cancer mortality among chemical plant workers exposed to formaldehyde. Toxicol Ind Health 2002(6):257–268.
Marsh GM, Youk AO, Buchanich JM, 2007a. Work in the metal industry and nasopharyngeal cancer mortality among formaldehyde exposed workers. Regul Toxicol Pharmacol 48(3):308–319.17544557
Marsh GM, Youk AO, Morfeld P. 2007b. Mis-specified and non-robust mortality risk models for nasopharyngeal cancer in the National Cancer Institute formaldehyde worker cohort study. Regul Toxicol Pharmacol 47(1):59–67.17000042
Matsunaga I, Miyake Y, Yoshida T, 2008. Ambient formaldehyde levels and allergic disorders among Japanese pregnant women: Baseline data from the Osaka maternal and child health study. Ann Epidemiol 18(1):78–84.18063241
Mautz WJ. 2003. Exercising animal models in inhalation toxicology: Interactions with ozone and formaldehyde. Environ Res 92(1):14–26.12706751
McGregor D, Bolt H, Cogliano V, 2006. Formaldehyde and glutaraldehyde and nasal cytotoxicity: Case study within the context of the 2006 IPCS human framework for the analysis of a cancer mode of action for humans. (Erratum in: Crit Rev Toxicol 37(4):353–354). Crit Rev Toxicol 36(10):821–835.17118731
McGwin G Jr., Lienert J 2010. Formaldehyde exposure and asthma in children: A systematic review. Environ Health Perspect 118 (3):313–317.20064771
Meding B, Swanbeck G. 1990. Occupational hand eczema in an industrial city. Contact Dermatitis 22:13–23.2138952
Medinsky M, Bond J. 2001. Sites and mechanisms for uptake of gases and vapors in the respiratory tract. Toxicology 160(1–3):165–172.11246136
Mendell MJ. 2007. Indoor residential chemical emissions as risk factors for respiratory and allergic effects in children: A review. Indoor Air 17(4):259–277.17661923
Merk O, Speit G. 1998. Significance of formaldehyde-induced DNA-protein crosslinks for mutagenesis. Environ Mol Mutagen 32(3):260–268.9814441
Merk O, Speit G. 1999. Detection of crosslinks with the comet assay in relationship to genotoxicity and cytotoxicity. Environ Mol Mutagen 33(2):167–172.10217071
Miyachi T, Tsutsui T. 2005. Ability of 13 chemical agents used in dental practice to induce sister-chromatid exchanges in Syrian hamster embryo cells. Odontology 93(1):24–29.16170472
Monticello TM, Miller FJ, Morgan KT. 1991. Regional increases in rat nasal epithelial cell proliferation following acute and subchronic inhalation of formaldehyde. Toxicol Appl Pharmacol 111:409–421.1746023
Monticello TM, Morgan KT, Everitt JI, 1989. Effects of formaldehyde gas on the respiratory tract of Rhesus monkeys. Am J Pathol 134:515–527.2923182
Monticello TM, Swenberg JA, Gross EA, 1996. Correlation of regional and nonlinear formaldehyde-induced nasal cancer with proliferating populations of cells. Cancer Res 56:1012–1022.8640755
Morgan KT. 1997. A brief review of formaldehyde carcinogenesis in relation to rat nasal pathology and human health risk assessment. Toxicol Pathol 25:291–307.9210261
Morgan KT, Gross EA, Patterson DL. 1986. Distribution, progression, and recovery of acute formaldehyde-induced inhibition of nasal mucociliary function of F-344 rats. Toxicol Appl Pharmacol 86:448–456.3787637
Moser B, Bodrogi F, Eibl G, 2005. Mass spectrometric profile of exhaled breath—field study by PTR-MS. Respir Physiol Neurobiol 145(2–3):295–300.15705543
Muller W, Engelhart G, Herbold B, 1993. Evaluation of mutagenicity testing with Salmonella typhimurium TA102 in three different laboratories. Environ Health Perspect 101:33–36.
NAS/NRC. 2007. Formaldehyde. In: Emergency and continuous exposure guidance levels for selected submarine contaminants. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 103–138. http://www.nap.edu/catalog.php?record_id=11170. May 15, 2008.
Nielsen G, Hougaard K, Larsen S, 1999. Acute airway effects of formaldehyde and ozone in BALB/c mice. Hum Exp Toxicol 18(6):400–409.10413245
NIOSH. 1992. NIOSH Recommendations for occupational safety and health: Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. DHHS NIOSH publication no. 92–100.
NIOSH. 2005. Formaldehyde. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. April 24, 2008.
NRC. 1986. National Research Council. Environmental tobacco smoke: Measuring exposures and assessing health effects. Washington, DC: National Academy Press.
NTP. 2005. Report on carcinogens. 11th ed. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. April 24, 2008.
NTP. 2008. Twelfth report on carcinogens (RoC). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/index.cfm?objectid=720162B0-BDB7-CEBA-FE2B27BBA2785BA5. May 14, 2008.
NTP. 2010. Final report on carcinogens background document for formaldehyde. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/twelfth/2009/November/Formaldehyde_BD_Final.pdf. January 22, 2010.
Ohtsuka R, Shutoh Y, Fujie H, 2003. Rat strain difference in histology and expression of Th1- and Th2-related cytokines in nasal mucosa after short term formaldehyde inhalation. Exp Toxicol Pathol 54(4):287–291.12710711
Orsiere T, Sari-Minodier I, Iarmarcovai G, 2006. Genotoxic risk assessment of pathology and anatomy laboratory workers exposed to formaldehyde by use of personal air sampling and analysis of DNA damage in peripheral lymphocytes. Mutat Res 605(1–2):30–41.16584911
OSHA. 2007a. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. http://www.osha.gov/comp-links.html. April 24, 2008.
OSHA. 2007b. Toxic and hazardous substances. Formaldehyde. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1048.
Ostojic L, Bradaric A, Mise K, 2006. Pulmonary function in persons who are professionally exposed to formaldehyde fumes. Coll Antropol 30(3):507–511.17058515
Overton J, Kimbell J, Miller F. 2001. Dosimetry modeling of inhaled formaldehyde: The human respiratory tract. Toxicol Sci 64(1):122–134.11606808
Ovrebo S, Aage H, Skaug V. 2002. Biotransformation of formaldehyde in cultured human bronchus. Environ Res 89(1):38–42.12051783
Ozen OA, Akpolat N, Songur A, 2005. Effect of formaldehyde inhalation on Hsp70 in seminiferous tubules of rat testes: An immunohistochemical study. Toxicol Ind Health 21(10):249–254.16463957
Ozen OA, Yaman M, Sarsilmaz M, 2003. Testicular zinc, copper and iron concentrations in male rats exposed to subacute and subchronic formaldehyde gas inhalation. (Erratum to: J Trace Elem Med Biol 16(2):119–122). J Trace Elem Med Biol 17(1):6.
Ozen OA, Yaman M, Sarsilmaz M, 2002. Testicular zinc, copper and iron concentrations in male rats exposed to subacute and subchronic formaldehyde gas inhalation. (Erratum in: J Trace Elem Med Biol 17(1):6). J Trace Elem Med Biol 16(2):119–122.12195726
Partanen T. 1993. Formaldehyde exposure and respiratory cancer—a meta-analysis of the epidemiologic evidence. Scand J Work Environ Health 19:8–15.8465176
Petushok N. 2000. Activity of glutathione-related enzymes in rat tissues after formaldehyde exposure. Curr Top Biophys 24(2):167–169.
Pinkerton L, Hein M, Stayner L. 2004. Mortality among a cohort of garment workers exposed to formaldehyde: An update. (Comment on: Occup Environ Med 61(11):875–876.) Occup Environ Med 61(3):193–200.
Pitten F, Kramer A, Herrmann K, 2000. Formaldehyde neurotoxicity in animal experiments. Pathol Res Pract 196(3):193–198.10729924
Pourmahabadian M, Azam K, Ghasemkhani M. 2006. Pulmonary function study between formaldehyde exposed and non-exposed staffs at some of the Tehran educational hospitals. J Med Sci 6(4):621–625.
Recio L, Sisk S, Pluta L, 1992. p53 mutations in formaldehyde-induced nasal squamous cell carcinomas in rats. Cancer Res 52:6113–6116.1394239
Restani P, Galli CL. 1991. Oral toxicity of formaldehyde and its derivatives. Crit Rev Toxicol 21:315– 328.1741947
Riedel F, Hasenauer E, Barth PJ, 1996. Formaldehyde exposure enhances inhalative allergic sensitization in the guinea pig. Allergy 51:94–99.8738514
Rumchev KB, Spickett JT, Bulsara MK, 2002. Domestic exposure to formaldehyde significantly increases the risk of asthma in young children. Eur Respir J 20:403–408.12212974
Rusch GM, Clary JJ, Rinehart WE, 1983. A 26-week inhalation toxicity study with formaldehyde in the monkey, rat, and hamster. Toxicol Appl Pharmacol 68:329–343.6857667
Saito Y, Nishio K, Yoshida Y, 2005. Cytotoxic effect of formaldehyde with free radicals via increment of cellular reactive oxygen species. Toxicology 210(2–3):235–245.15840437
Sakamoto T, Doi S, Torii S. 1999. Effects of formaldehyde, as an indoor air pollutant, on the airway. Allergol Int 48(3):151–160.
Saillenfait AM, Bonnet P, De Ceaurriz J. 1989. The effects of maternally inhaled formaldehyde on embryonal and foetal development in rats. Food Chem Toxicol 27 (8):545–548.2792978
Sandikci M, Eren U, Kum S. 2007. Effects of formaldehyde and xylene on alpha-naphthyl acetate esterase positive T-lymphocytes in bronchus associated lymphoid tissue and peripheral blood in rats. Rev Med Vet (Toulouse) 158(6):297–301.
Sari DK, Kuwahara S, Tsukamoto Y. 2004. Effect of prolonged exposure to low concentrations of formaldehyde on the corticotropin releasing hormone neurons in the hypothalamus and adrenocorticotropic hormone cells in the pituitary gland in female mice. Brain Res 1013(1):107–116.15196973
Sari-Minodier I, Orsiere T, Auquier P, 2001. Use of the micronucleus assay in the assessment of mutagenic risk: Study of ten workers occupationally exposed to formaldehyde. Arch Mal Prof 62(2):75–– 82.
Sarsilmaz M, Kaplan S, Songur A, 2007. Effects of postnatal formaldehyde exposure on pyramidal cell number, volume of cell layer in hippocampus and hemisphere in the rat: A stereological study. Brain Res 1145:157–167.17346681
Sarsilmaz M, Oguz A, Akpolat N, 1999. The histopathologic effects of inhaled formaldehyde on Leydig cells of the rats in subacute period. Firat Üniveristesi Sağlic Bilimieri Tip Dergisi 13(1):37–40.
Schachter EN, Witek TJ J, Tosun T, 1986. A study of respiratory effects from exposure to 2 ppm formaldehyde in healthy subjects. Arch Environ Health 41:229–239.3767432
Schlink K, Janssen K, Nitzsche S, 1999. Activity of O6-methylguanine DNA methyltransferase in mononuclear blood cells of formaldehyde-exposed medical students. Arch Toxicol 72(1):15–21.
Schlosser P, Lilly P, Conolly R, 2003. Benchmark dose risk assessment for formaldehyde using airflow modeling and a single-compartment, DNA-protein cross-link dosimetry model to estimate human equivalent doses. Risk Anal 23(3):473–487.12836840
Schlosser PM. 1999. Relative roles of convection and chemical reaction for the disposition of formaldehyde and ozone in nasal mucus. Inhal Toxicol 11(10):967–980.10509029
Schmid O, Speit G. 2007. Genotoxic effects induced by formaldehyde in human blood and implications for the interpretation of biomonitoring studies. Mutagenesis 22(1):69–74.17158519
Senichenkova IN, Chebotar NA. 1996. Effect of gasoline and formaldehyde on prenatal development of rats with induced micronutrient disorder (iron deficiency). Ontogenez 27(2):108–113.8725437
Senichenkova IN. 1991. Embryotoxic effect of pollutants in the industrial environment: Formalehdye and gasoline. Institute of Obstetrics and Gynecology, Academy of Medical Sciences of the USSR, Leningrad.
Shaham J, Bomstein Y, Gurvich R, 2003. DNA-protein crosslinks and p53 protein expression in relation to occupational exposure to formaldehyde. Occup Environ Med 60(6):403–409.12771391
Shaham J, Bomstein Y, Meltzer A, 1996. DNA-protein crosslinks, a biomarker of exposure to formaldehyde—in vitro and in vivo studies. Carcinogenesis 17:121–125.8565120
Shaham J, Gurvich R, Kaufman Z. 2002. Sister chromatid exchange in pathology staff occupationally exposed to formaldehyde. Mutat Res 514(1–2):115–123.11815250
Smedje G, Norback D, Edling C. 1997. Asthma among secondary schoolchildren in relation to the school environment. Clin Exp Allergy 27:1270–1278.9420130
Soffritti M, Belposggi F, Lambertini L, 2002. Results of long-term experimental studies on the carcinogenicity of formaldehyde and acetaldehyde in rats. Ann N Y Acad Sci 982:87–105.12562630
Soffritti M, Maltoni C, Maffei F, 1989. Formaldehyde: An experimental multipotential carcinogen. Toxicol Ind Health 5:699–730.2815102
Sogut S, Songur A, Ozen O, 2004. Does the subacute (4-week) exposure to formaldehyde inhalation lead to oxidant/antioxidant imbalance in rat liver? Eur J Gen Med 1(3):26–32.
Songur A, Kus I, Sahin S, 2005. The changes of zinc, copper, and iron levels in lung tissue after formaldehyde inhalation during the early postnatal period of rats. Eur J Gen Med 2(2):62–68.
Sorg BA, Bailie TM, Tschirgi ML, 2001. Exposure to repeated low-level formaldehyde in rats increases basal corticosterone levels and enhances the corticosterone response to subsequent formaldehyde. Brain Res 898(2):314–320.11306018
Speit G, Schmid O, Frohler-Keller M, 2007a. Assessment of local genotoxic effects of formaldehyde in humans measured by the micronucleus test with exfoliated buccal mucosa cells. Mutat Res 627(2):129–135.17174593
Speit G, Schutz P, Hogel J. 2007b. Characterization of the genotoxic potential of formaldehyde in V79 cells. Mutagenesis 22(6):387–394.17855734
SRI. 1992. Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute International, 677–678.
SRI. 2007. Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute International, 648.
Stayner L, Smith AB, Reeve G, 1985a. Proportionate mortality study of workers in the garment industry exposed to formaldehyde [Letter]. Am J Ind Med 8:75–76.4025341
Stayner L, Smith AB, Reeve G, 1985b. Proportionate mortality study of workers in the garment industry exposed to formaldehyde. Am J Ind Med 7:229–240.3985015
Stayner LT, Elliott L, Blade L, 1988. A retrospective cohort mortality study of workers exposed to formaldehyde in the garment industry. Am J Ind Med 13:667–681.3389362
Stone RA, Youk AO, Marsh GM, 2001. Historical cohort study of US man-made vitreous fiber production workers: IV Quantitative exposure-response analysis of the nested case-control study of respiratory system cancer. J Occup Environ Med 43(9):779–792.11561361
Subramaniam R, Chen C, Crump K, 2007. Uncertainties in the CIIT 2-stage model for formaldehyde-induced nasal cancer in the F-344 rat: A limited sensitivity analysis. Risk Anal 27(5):1237–1254.18076493
Subramaniam R, Chen C, Crump K, 2008. Uncertainties in biologically-based modeling of formaldehyde-induced cancer risk: Identification of key issues. Risk Anal 28(4)907–923.18564991
Subramaniam RP, Richardson RB, Morgan KT, 1998. Computational fluid dynamics simulations of inspiratory airflow in the human nose and nasopharynx. Inhal Toxicol 10:473–502.
Sul D, Kim H, Oh E. 2007. Gene expression profiling in lung tissues from rats exposed to formaldehyde. Arch Toxicol 81(8):589–597.17285311
Takahashi K, Morita T, Kawazoe Y. 1985. Mutagenic characteristics of formaldehyde on bacterial systems. Mutat Res 156:153–161.3889633
Takahashi M, Hasegawa R, Furukawa F, 1986. Effects of ethanol, potassium metabisulfite, formaldehyde and hydrogen peroxide on gastric carcinogenesis in rats after initiation with n-methyl-n nitro-n-nitrosoguanidine. Jpn J Cancer Res 77:118–124.3082823
Takahashi S, Tsuji K, Fujii K, 2007. Prospective study of clinical symptoms and skin test reactions in medical students exposed to formaldehyde gas. J Dermatol 34(5):283–289.17408435
Takeuchi A, Takigawa T, Abe M, 2007. Determination of formaldehyde in urine by headspace gas chromatography. Bull Environ Contam Toxicol 79(1):1–4.17618393
Takigawa T, Usami M, Yamasaki Y, 2005. Reduction of indoor formaldehyde concentrations and subjective symptoms in a gross anatomy laboratory. Bull Environ Contam Toxicol 74(6):1027–1033.16158836
Tarkowski M, Gorski P. 1995. Increased IgE antiovalbumin level in mice exposed to formaldehyde. Int Arch Allergy Immunol 106:422–424.7719158
Taskinen HK, Kyyronen P, Sallmen M, 1999. Reduced fertility among female wood workers exposed to formaldehyde. Am J Ind Med 36:206–212.10361608
Tavernier G, Fletcher G, Gee I, 2006. IPEADAM study: Indoor endotoxin exposure, family status, and some housing characteristics in English children. J Allergy Clin Immunol 117:656–662.16522467
Teng S, Beard K, Pourahmad J, 2001. The formaldehyde metabolic detoxification enzyme systems and molecular cytotoxic mechanism in isolated rat hepatocytes. Chem Biol Interact 130–132(1–3):285– 296.
Thomas R, Allen B, Nong A, 2007. A method to integrate benchmark dose estimates with genomic data to assess the functional effects of chemical exposure. Toxicol Sci 98(1):240–248.17449896
Til HP, Woutersen VJ, Feron V, 1989. Two-year drinking-water study of formaldehyde in rats. Food Chem Toxicol 27:77–87.2714719
Tomlin C. 2003. Formaldehyde (404). The e-pesticide manual. Surrey, UK: British Crop Protection Council.
TRI06. 2008. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. February 27, 2008.
Triebig G, Zober MA. 1984. Indoor air pollution by smoke constituents—a survey. Prev Med 13:570– 581.6399372
Usanmaz S, Akarsu E, Vural N. 2002. Neurotoxic effects of acute and subacute formaldehyde exposures in mice. Environ Toxicol Pharmacol 11(2):93–100.21782590
Ushio H, Nohara K, Fujimaki H. 1999. Effect of environmental pollutants on the production of proinflammatory cytokines by normal human dermal keratinocytes. Toxicol Lett 105(1):17–24.10092052
Vandenplas O, Fievez P, Delwiche JP, 2004. Persistent asthma following accidental exposure to formaldehyde. Allergy 59(1):115–116.14674947
Vasudeva N, Anand C. 1996. Cytogenetic evaluation of medical students exposed to formaldehyde vapor in the gross anatomy dissection level. J Am Coll Health 44:177–179.8583043
Vaughan TL, Stewart PA, Teschke K. 2000. Occupational exposure to formaldehyde and wood dust and nasopharyngeal carcinoma. Occup Environ Med 57(6):376–384.10810126
Venn AJ, Cooper M, Antoniak M, 2003. Effects of volatile organic compounds, damp, and other environmental exposures in the home on wheezing illness in children. Thorax 58:955–960.14586048
Viccellio P, Bania T, Brent J, , eds. 1998. Formaldehyde. In: Emergency toxicology. Philadelphia, PA: Lippincott-Raven Publishers, 519–522.
Wantke F, Demmer CM, Tappler P, 1996a. Exposure to gaseous formaldehyde induces IgE-mediated sensitization to formaldehyde in school-children. Clin Exp Allergy 26:276–280.8729664
Wantke F, Focke M, Hemmer W, 1996b. Formaldehyde and phenol exposure during an anatomy dissection course: A possible source of IgE-mediated sensitization? Allergy 51:837–841.8947343
Wei CN, Harada K, Ohmori S, 2007. Subjective symptoms of medical students exposed to formaldehyde during a gross anatomy dissection course. Int J Immunopathol Pharmacol 20(2):23–25.
WHO. 1986. Indoor air quality: Radon and formaldehyde. Report on a WHO meeting. Dubrovnik 26-– 30 August 1985. Copenhagen: World Health Organization Regional Office for Europe.
WHO. 1989. Formaldehyde. Environmental health criteria 89. Geneva: United Nations Environment Programme. International Labour Organisation. World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc89.htm. April 16, 2008.
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. March 08, 2006.
WHO. 2002. Concise International Chemical Assessment Document 40. Formaldehyde. Geneva: World Health Organization.
WHO. 2004. Guidelines for drinking-water quality. Volume 1. Recommendations. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Witek TJ J, Schachter EN, Tosun T, 1987. An evaluation of respiratory effects following exposure to 2.0 ppm formaldehyde in asthmatics: Lung function, symptoms, and airway reactivity. Arch Environ Health 42:230–237.3310924
Wood RW, Coleman JB. 1995. Behavioral evaluation of the irritant properties of formaldehyde. Toxicol Appl Pharmacol 130:67–72.7839371
Woutersen RA, Appleman LM, Wilmer JW, 1987. Subchronic (13-week) inhalation toxicity study of formaldehyde in rats. J Appl Toxicol 7:43–49.3611596
Xu B, Aoyama K, Takeuchi M, 2002. Expression of cytokine mRNAs in mice cutaneously exposed to formaldehyde. Immunol Lett 84(1):49–55.12161283
Yanagawa Y, Kaneko N, Hatanaka K, 2007. A case of attempted suicide from the ingestion of formalin. Clin Toxicol 45(1):72–76.
Yang Y, Xi Z, Chao F, 2005. Effects of formaldehyde inhalation on lung of rats. Biomed Environ Sci 18(3):164–168.16131018
Ye X, Yan W, Xie H, 2005. Cytogenetic analysis of nasal mucosa cells and lymphocytes from high-level long-term formaldehyde exposed workers and low-level short-term exposed waiters. Mutat Res 588(1):22–27.16257574
Ying CJ, Ye XL, Xie H, 1999. Lymphocyte subsets and sister-chromatid exchanges in the students exposed to formaldehyde vapor. Biomed Environ Sci 12(2):88–94.10560533
Youk AO, Marsh GM, Stone RA, 2001. Historical cohort study of US man-made vitreous fiber production: III. Analysis of exposure-weighted measures of respirable fibers and formaldehyde in the nested case-control study of respiratory system cancer. J Occup Environ Med 43(9):767–778.11561360
Zararsiz I, Sonmez M, Yilmaz H, 2006. Effects of omega-3 essential fatty acids against formaldehyde-induced nephropathy in rats. Toxicol Ind Health 22(5):223–229.16898265
Zhang L, Steinmaus C, Eastmond DA, 2009. Formaldehyde exposure and leukemia: A new meta-analysis and potential mechanisms. Mutat Res 681:150–168.18674636
Zhong W, Que Hee S. 2004. Formaldehyde-induced DNA adducts as biomarkers of in vitro human nasal epithelial cell exposure to formaldehyde. Mutat Res 563(1):13–24.15324745
Zhou D, Qiu S, Zhang J, 2006. The protective effect of vitamin E against oxidative damage caused by formaldehyde in the testes of adult rats. Asian J Androl 8(5):584–585.16751993
Zwart A, Woutersen RA, Wilmer JWGM, 1988. Cytotoxic and adaptive effects in rat nasal epithelium after 3-day and 13-week exposure to low concentrations of formaldehyde vapour. Toxicology 51:87–99.3413803