# 7 REGULATIONS, ADVISORIES, AND GUIDELINES

The EPA oral reference dose (RfD) for formaldehyde is 0.2 mg/kg/day for causing gastrointestinal damage (IRIS 2010). EPA began a reassessment of the inhalation reference concentration (RfC) in January 1998, and a draft assessment was released for public comment in June 2010. A committee of the NRC is conducting an independent scientific review of this EPA draft human health assessment of formaldehyde for IRIS (IRIS 2010). The committee will provide a brief report that comments on EPA’s identification of potential adverse non-cancer health effects, assessment of carcinogenic potential, exposure-response analysis for identified end points, quantitative risk assessment methods, and evaluation of sources of uncertainty in the health assessment.

The international and national regulations, advisories, and guidelines regarding formaldehyde in air, water, and other media are summarized in Table 7-1.

The National Toxicology Program (NTP) (2005) noted that formaldehyde is reasonably anticipated to be a human carcinogen. NTP has included formaldehyde as an item under consideration for the Twelfth Report on Carcinogens (NTP 2008, 2010). In 2006, the International Agency for Research on Cancer (IARC) has reclassified formaldehyde from Group 2A to Group 1 (IARC 2008). The EPA has classified formaldehyde as a B1 compound, probable human carcinogen, on the basis of limited evidence in humans and sufficient evidence in animals (IRIS 2010).

Formaldehyde is on the list of chemicals subject to the requirements of The Emergency Planning and Community Right-to-Know Act of 1986 (EPCRA) (EPA 2008c). Section 313 of Title III of EPCRA requires owners and operators of certain facilities that manufacture, import, process, or otherwise use the chemicals on this list to report annually their release of those chemicals to any environmental media (EPA 2008c).

OSHA requires employers of workers who are occupationally exposed to formaldehyde to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PELs). The employer must use controls and practices, if feasible, to reduce exposure to or below an 8-hour time-weighted average (TWA) of 0.75 ppm. The 15-minute, short-term exposure limit (STEL) for formaldehyde is 2 ppm (OSHA 2007b).

The EPA regulates formaldehyde under the Clean Air Act (CAA) and has designated formaldehyde as a hazardous air pollutant (HAP) (EPA 2008c); formaldehyde is listed among the urban HAPs for the Integrated Urban Air Toxics Strategy (EPA 1999). The major source category for which formaldehyde emissions are controlled is the Synthetic Organic Chemicals Manufacturing Industry (SOCMI) (EPA 2008e, 2008i).

Under the Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA), owners of vessels or facilities are required to immediately report release of formaldehyde equal to or greater than the reportable quantity of 100 pounds (45.4 kg) (EPA 2008c).

The Food and Drug Administration (FDA) identifies formaldehyde as an indirect food additive for use only as a component of adhesives (FDA 2007b). When used in accordance with specified conditions, the food additive, formaldehyde, is permitted in feed and drinking water of animals (FDA 2007a).

Table 7-1 Regulations, Advisories, and Guidelines Applicable to Formaldehyde

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | Group 1^a^ | IARC 2008
WHO | Air quality guidelines^b^ | 0.1 mg/m^3^ | WHO 2000
| Drinking water quality guidelines | 0.9 mg/L | WHO 2004
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (ceiling limit) | 0.3 ppm | ACGIH 2007
| TLV basis (critical effects)^c^ | Upper respiratory tract and eye irritation
AIHA | ERPG-1^d^ | 1 ppm | AIHA 1988
| ERPG-2^d^ | 10 ppm
| ERPG-3^d^ | 25 ppm
EPA | AEGL-1^e^ | | EPA 2007a
| 10 minutes | 0.90 mg/m^3^
| 30 minutes | 0.90 mg/m^3^
| 60 minutes | 0.90 mg/m^3^
| 4 hours | 0.90 mg/m^3^
| 8 hours | 0.90 mg/m^3^
| AEGL-2^e^
| 10 minutes | 14 mg/m^3^
| 30 minutes | 14 mg/m^3^
| 60 minutes | 14 mg/m^3^
| 4 hours | 14 mg/m^3^
| 8 hours | 14 mg/m^3^
| AEGL-3^e^
| 10 minutes | 100 mg/m^3^
| 30 minutes | 70 mg/m^3^
| 60 minutes | 56 mg/m^3^
| 4 hours | 35 mg/m^3^
| 8 hours | 35 mg/m^3^
| Second list of AEGL priority chemicals for guideline development | Yes | EPA 2008a
| Hazardous air pollutant (HAP) | Yes | EPA 2007b; 42 USC 7412
| Listed on the Urban HAPs for the Integrated Urban Air Toxics Strategy | Yes | EPA 1999; 64 FR 38706
| National emission standards for organic hazardous air pollutants from the SOCMI | Yes | EPA 2008i; 40 CFR 68.107, Table 2
EPA | Regulated toxic substances and threshold quantities for accidental release prevention under Section 112(r) of the Clean Air Act | 15,000 pounds | EPA 2008g; 40 CFR 68.130
| Standards of performance for equipment leaks of VOC in SOCMI | Yes | EPA 2008e; 40 CFR 68.489
NIOSH | REL (10-hour TWA) | 0.016 ppm | NIOSH 2005
| Ceiling limit (15-minute) | 0.1 ppm
| IDLH | 20 ppm
| Target organs | Eyes and respiratory system
| Potential occupational carcinogen | Yes
| Category of pesticides | Group 1 pesticide^f^ | NIOSH 1992
OSHA | PEL (8-hour TWA) for general, shipyard, and construction industry (ceiling limit) | 0.75 ppm | OSHA 2007b; 29 CFR; 1910.1048
| STEL (15-minute) | 2 ppm
| Highly hazardous chemical which present a potential for a catastrophic event or above the threshold quantity | Yes | OSHA 2007a; 29 CFR 1910.119
| Threshold quantity | 1,000 pounds
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2008b; 40 CFR 116.4
| Drinking water standards and health advisories | | EPA 2006a
| 1-day health advisory for a 10-kg child | 10 mg/L
| 10-day health advisory for a 10-kg child | 5 mg/L
| DWEL | 7 mg/L
| Lifetime | 1 mg/L
| National primary drinking water standards | No data | EPA 2003
| National recommended water quality criteria | No data | EPA 2006b
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | 100 pounds | EPA 2008d; 40 CFR 117.3
c. Food
FDA | EAFUS^g^ | Yes | FDA 2008
| Indirect food additives: adhesives and components of coatings | Yes | FDA 2007b; 21 CFR 175.105
| Food additive permitted in feed and drinking water of animals | Yes | FDA 2007a; 21 CFR 573.460
d. Other
ACGIH | Carcinogenicity classification | A2^h^ | ACGIH 2007
EPA | Carcinogenicity classification | Group B1^i^ | IRIS 2010
| RfC | Under review
| RfD | 0.2 mg/kg/day
| Master Testing List | Yes^j^ | EPA 2008h
| Superfund, emergency planning, and community right-to-know
| Designated CERCLA hazardous substance | Yes^k^ | EPA 2008c; 40 CFR 302.4
| Reportable quantity | 100 pounds
| Effective date of toxic chemical release reporting | 01/01/1987 | EPA 2008j; 40 CFR 372.65
| Extremely Hazardous Substances | | EPA 2008f; 40 CFR 355, Appendix A
| Reportable quantity | 100 pounds | EPA 2008f; 40 CFR 355, Appendix A
| Threshold planning quantity | 500 pounds | EPA 2008f; 40 CFR 355, Appendix A
| Identification and listing of hazardous waste | | EPA 2008l; 40 CFR 261, Appendix VIII
| Hazardous waste number | U122 | EPA 2008l; 40 CFR 261, Appendix VIII
NTP | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2005
| Twelfth report on carcinogens; items under consideration | Yes | NTP 2008

a Group 1: The agent is carcinogenic to humans.

b TWA based on effects other than cancer or odor/annoyance using an averaging time of 30 minutes.

c Sensitization designation refers to the potential for an agent to produces sensitization, as confirmed by human or animal data.

d ERPG-1 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without experiencing other than mild, transient health effects; ERPG-2 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without experiencing irreversible or other serious adverse effects; and ERPG-3 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without life-threatening health effects (AIHA 1988).

e AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects; however, the effects are not disabling and are transient and reversible upon cessation of exposure; AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape; and AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death (EPA 2007a).

f Group 1 pesticide: contains the pesticides that pose a significant risk of adverse acute heatlh effects at low concentrations.

g The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

h A2: Suspected human carcinogen.

i Group B1: Probable human carcinogen, based on limited evidence in humans, and sufficient evidence in animals.

j Formaldehyde was recommended to the MTL by Office of Pollution Prevention and Toxics in 1992 and the chemical testing program is currently underway under a voluntary testing agreement for emissions testing.

k Designated CERCLA hazardous substance pursuant to Section 311(b)(2) of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of the Resource Conservation and Recovery Act.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = Emergency Response Planning Guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = Generally Recognized As Safe; HAP = hazardous air pollutant; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; SOCMI = Synthetic Organic Chemicals Manufacturing Industry; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; VOC = volatile organic compounds; WHO = World Health Organization