# 6 ANALYTICAL METHODS

## 6.1 BIOLOGICAL MATERIALS

Takeuchi et al. (2007) developed a technique for quantifying formaldehyde in urine by derivatization with O-(2,3,4,5,6-pentafluorobenzyl)hydroxylamine (PFBHA) to the PFBHA-formaldoxime, using a headspace sampler coupled to a gas chromatograph equipped with an electron capture detector (ECD) (see Table 6-1).

Table 6-1 Analytical Methods for Determining Formaldehyde in Biological Materials

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Urine | Derivatization with O-(2,3,4,5,6-pentafluorobenzyl)-hydroxylamine. | GC/EC | 1.08 μg/L | 99 | Takeuchi et al. 2007

GC/EC = gas chromatography/electron capture

## 6.2 ENVIRONMENTAL SAMPLES

The most widely used methods for the determination of the concentration of formaldehyde in air are based on ultraviolet/visible (UV/VIS) spectrophotometry measurements of the absorption band at 580 nm following derivitization with chromotropic and sulfuric acid. Sensitivities of 0.01–0.03 mg/m^3^ can be achieved by use of these methods. Other methods include colorimetry, fluorimetry, high--performance liquid chromatography (HPLC), polarography, gas chromatography (GC), infrared detection, and gas detector tubes. Most methods require the formation of a formaldehyde derivative for separation and detection (IARC 2006). Formaldehyde determination by use of HPLC can achieve a limit of detection of ≤2 μg/m^3^, and HPLC is the most sensitive method. Gas detection tubes that have sensitivities of about 0.05–0.12 μg/m^3^ (0.04–0.1 ppm) and infrared analyzers that have sensitivities of about 1.2–230 μg/m^3^ (1–110 ppb) are often used to monitor workplace atmospheres (IARC 2006).

One type of passive sampler uses a glass fiber filter or a tape impregnated with 2,4-dinitrophenylhydrazine (DNPH) and phosphoric acid mounted in a polystyrene cassette (see Table 6-2). SKC Inc. and GMD Systems use this passive sampling method for commercially available badges (Levin and Lindahl 1994; Levin et al. 1989).

Table 6-2 Analytical Methods for Determining Formaldehyde in Environmental Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Air | Preparation of passive monitor, formaldehyde in air adsorbs onto DNPH and sulfuric acid impregnated glass fiber filter or tape | UV/VIS absorbance at 365 nm | 6 μg/m^3^ (5 ppb) (8 hours); 1.2 μg/m^3^ (1 ppb) (24 hours) | 100% (5% RSD) | Levin and Lindahl 1994; Levin et al. 1989
Air | Drawing of air through a sampling tube containing silica gel coated with DNPH. Elution of derivative with acetonitrile. | GC/NPD | 0.12 μg/sample | >95 | Jeong and Paik 2005
Atmospheric water | Reaction of formaldehyde in water with ammonium acetate and 2,4-pentanedione in FIA system to form 3,5-diacetyl-1,4-dihydro-lutidine. | FIA/fluorescence | 3 μg/L (3 ppb) | No data | Dong and Dasgupta 1987

DNPH = 2,4-dinitrophenylhydrazine; FIA = flow injection analysis; GC = gas chromatography; NPD =nitrogen-phosphorus detector; RSD = relative standard deviation; UV/VIS = ultraviolet/visible absorbance detection

Jeong and Paik (2005) have reported a method in which the DNPH formaldehyde derivatives are analyzed by use of GC equipped with a nitrogen-phosphorus detector (GC-NPD) in order to measure personal exposure in the workplace. In laboratory tests, this new method, referred to as the GC-NPD method, is as sensitive as the NIOSH analytical method, which uses HPLC equipped with an ultraviolet detector (Jeong and Paik 2005).

The method of Dong and Dasgupta (1987) relies on the reaction of formaldehyde in atmospheric water with a diketone (2,4-pentanedione) and ammonium acetate to form a fluorescent derivative that is measured spectrophotometrically in a flow injection analysis system.

## 6.3 ADEQUACY OF THE DATABASE

### 6.3.2 Ongoing Studies

The information in Table 6-3 was found as a result of a search of the Federal Research in Progress database (FEDRIP 2008).

The Environmental Health Laboratory Sciences Division of the National Center for Environmental Health, Centers for Disease Control and Prevention, is developing methods for the analysis of formaldehyde and other volatile organic compounds in blood. These methods use purge and trap methodology, high-resolution gas chromatography, and magnetic sector mass spectrometry, which give detection limits in the low parts per trillion (ppt) range.

Table 6-3 Ongoing Studies on Formaldehyde

Investigator | Affiliation | Research description | Sponsor
Kretzschmar, Ilona | CUNY City College | This study describes a method for the generation of porous, cylindrical polymer membranes with a uniform catalyst coating that will lead to the development of new material for the separation and decomposition of formaldehyde in indoor air streams. | National Science Foundation
Marotta, Christopher L | Eltron Research, Inc. | Researchers are conducting a study to develop a small, inexpensive sensor for measuring the concentration of formaldehyde in real-time in order to protect workers who encounter formaldehyde in the chemical industry. The aim is also to create a sensor platform that can be readily adapted for indoor air quality or environmental monitoring applications. | NIOSH

CUNY = City University of New York; NIOSH = National Institute for Occupational Safety and Health

Source: FEDRIP 2008