# 5 POTENTIAL FOR HUMAN EXPOSURE

## 5.1 OVERVIEW

Formaldehyde has been identified in at least 29 of the 1,699 hazardous waste sites that have been proposed for inclusion on the EPA National Priorities List (NPL) (HazDat 2008). However, the number of sites evaluated for formaldehyde is not known.

In December 2007 and January 2008, the Centers for Disease Control and Prevention (CDC) tested travel trailers, park models, and mobile homes provided by the Federal Emergency Management Agency (FEMA) as temporary housing to Gulf Coast residents in Louisiana and Mississippi who were displaced by Hurricanes Katrina and Rita. The results showed an average indoor air concentration of 77 ppb, with measured levels ranging from 3 to 590 ppb; the range is higher than typical background indoor air concentrations of 10–30 ppb (CDC 2008). Formaldehyde levels are generally lower in cooler temperatures and lower humidity; therefore, levels measured in this study are likely to underestimate those that would occur in the summer months (CDC 2008).

## 5.2 RELEASES TO THE ENVIRONMENT

The Toxics Release Inventory (TRI) data should be used with caution because only certain types of facilities are required to report their releases (EPA 2005). TRI is not an exhaustive list. Manufacturing and processing facilities are required to report information to the TRI only if they employ 10 or more fulltime employees; if their facility is included in Standard Industrial Classification (SIC) Codes 10 (except 1011, 1081, and 1094), 12 (except 1241), 20–39, 4911 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4931 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4939 (limited to facilities that combust coal and/or oil for the purpose of generating electricity for distribution in commerce), 4953 (limited to facilities regulated under RCRA Subtitle C, 42 U.S.C. section 6921 et seq.), 5169, 5171, and 7389 (limited S.C. section 6921 et seq.), 5169, 5171, and 7389 (limited to facilities primarily engaged in solvents recovery services on a contract or fee basis); and if their facility produces, imports, or processes ≥25,000 pounds of any TRI chemical or otherwise uses >10,000 pounds of a TRI chemical in a calendar year (EPA 2005).

### 5.2.1 Air

Estimated releases of 8.88 million pounds (~4,028 metric tons) of formaldehyde to the atmosphere from 725 domestic manufacturing and processing facilities in 2006 accounted for about 41% of the estimated total environmental releases from facilities required to report to the TRI (TRI06 2008). These releases are summarized in Table 5-1.

Table 5-1 Releases to the Environment from Facilities that Produce, Process, or Use Formaldehyde^a^

| | Reported amounts released in pounds per year^b^
| | | | | | | Total release
State^c^ | RF^d^ | Air^e^ | Water^f^ | UI^g^ | Land^h^ | Other^i^ | On-site^j^ | Off-site^k^ | On- and off-site
AK | 1 | 3,871 | 0 | 0 | 250 | 0 | 3,871 | 250 | 4,121
AL | 37 | 417,877 | 37,125 | 0 | 2,125 | 0 | 455,597 | 1,530 | 457,127
AR | 15 | 292,714 | 19,719 | 0 | 1,012 | 0 | 312,483 | 963 | 313,446
AZ | 4 | 9,813 | No data | 0 | 1 67 | 0 | 9,813 | 1 67 | 9,980
CA | 26 | 196,556 | 10 | 0 | 3,267 | 750 | 197,263 | 3,320 | 200,583
CO | 1 | 0 | No data | 0 | 0 | 0 | 0 | 0 | 0
CT | 5 | 21,647 | 1,078 | 0 | 2,230 | 1,096 | 22,725 | 3,326 | 26,051
DE | 1 | 1,965 | 0 | 0 | 0 | 0 | 1,965 | 0 | 1,965
FL | 15 | 295,914 | 19,431 | 89,497 | 423 | 0 | 405,265 | 0 | 405,265
GA | 35 | 795,077 | 19,572 | 0 | 1,317 | 805 | 814,677 | 2,094 | 816,771
IA | 16 | 156,218 | 4,554 | 10,868 | 5 | 0 | 160,772 | 10,873 | 171,645
ID | 1 | 25,410 | 5,600 | 0 | 0 | 0 | 31,010 | 0 | 31,010
IL | 32 | 59,702 | 2,818 | 0 | 5,662 | 518 | 62,520 | 6,180 | 68,700
IN | 13 | 74,451 | No data | 0 | 19,402 | 1,550 | 74,451 | 20,952 | 95,403
KS | 11 | 112,150 | 0 | 0 | 201 | 0 | 112,150 | 201 | 112,351
KY | 14 | 40,966 | 6,018 | 0 | 0 | 0 | 46,984 | 0 | 46,984
LA | 32 | 394,829 | 28,805 | 10,818,233 | 19,874 | 0 | 11,257,892 | 3,849 | 11,261,741
MA | 10 | 53,737 | 6,490 | 0 | 1,336 | 377 | 60,227 | 1,713 | 61,940
MD | 4 | 22,113 | No data | 0 | 0 | 0 | 22,113 | 0 | 22,113
ME | 8 | 236,773 | 5,693 | 0 | 766 | 0 | 242,481 | 751 | 243,232
MI | 26 | 144,342 | 1,837 | 9 | 65,194 | 9 | 146,182 | 65,209 | 211,391
MN | 12 | 121,667 | 0 | 0 | 8 | 0 | 121,675 | 0 | 121,675
MO | 12 | 34,045 | 311 | 0 | 9,541 | 0 | 34,361 | 9,536 | 43,897
MS | 11 | 311,085 | 2,539 | 0 | 239 | 0 | 313,624 | 239 | 313,863
MT | 4 | 591,312 | 60 | 0 | 45 | 0 | 591,414 | 3 | 591,417
NC | 42 | 503,529 | 31,057 | 0 | 16,581 | 776 | 536,450 | 15,493 | 551,943
NE | 7 | 49,763 | 0 | 0 | 5 | 0 | 49,768 | 0 | 49,768
NH | 2 | 2,808 | 1 28 | 0 | 1 | 0 | 2,936 | 1 | 2,937
NJ | 10 | 2,564 | 0 | 0 | 32 | 0 | 2,596 | 0 | 2,596
NV | 1 | 0 | No data | 0 | 0 | 0 | 0 | 0 | 0
NY | 19 | 80,795 | 27,272 | 0 | 480 | 5,105 | 108,179 | 5,473 | 113,652
OH | 39 | 397,719 | 1,160 | 235,776 | 98,696 | 0 | 466,416 | 266,935 | 733,351
OK | 8 | 184,179 | 1,837 | 0 | 5 | 0 | 186,021 | 0 | 186,021
OR | 27 | 873,071 | 10,970 | 0 | 1,511 | 0 | 884,047 | 1,505 | 885,552
PA | 26 | 371,071 | 3,875 | 0 | 5,263 | 43 | 374,959 | 5,293 | 380,252
PR | 2 | 1,1 61 | No data | 0 | 0 | 2,617 | 1,161 | 2,617 | 3,777
RI | 3 | 15 | No data | 0 | 0 | 0 | 15 | 0 | 15
SC | 33 | 682,966 | 31,124 | 0 | 23,447 | 0 | 719,275 | 18,262 | 737,537
SD | 2 | 42,541 | No data | 0 | 0 | 0 | 42,541 | 0 | 42,541
TN | 12 | 88,806 | 13,563 | 0 | 562 | 1 61 | 102,369 | 723 | 103,092
TX | 68 | 561,366 | 6,079 | 808,681 | 14,573 | 2,216 | 1,371,887 | 21,028 | 1,392,915
UT | 3 | 8,081 | No data | 0 | 28 | 48 | 8,081 | 76 | 8,157
VA | 15 | 166,330 | 971 | 0 | 2,672 | 0 | 168,611 | 1,362 | 169,974
VT | 1 | 253 | No data | 0 | 20 | 0 | 253 | 20 | 273
WA | 13 | 147,481 | 32,723 | 0 | 973 | 90 | 180,204 | 1,063 | 181,267
WI | 32 | 140,158 | 7,721 | 0 | 5,394 | 5 | 152,839 | 439 | 153,278
WV | 12 | 84,897 | 555 | 0 | 229 | 0 | 85,456 | 225 | 85,681
WY | 2 | 75,715 | No data | 0 | 0 | 0 | 75,715 | 0 | 75,715
Total | 725 | 8,879,500 | 330,696 | 11,963,064 | 303,537 | 16,166 | 21,021,291 | 471,671 | 21,492,962

a The TRI data should be used with caution, since only certain types of facilities are required to report. TRI is not an exhaustive list. Data are rounded to nearest whole number.

b Data in TRI are maximum amounts released by each facility.

c Post office state abbreviations are used.

d Number of reporting facilities.

e The sum of fugitive and point source releases are included in releases to air by a given facility.

f Surface water discharges, waste water treatment (metals only), and publicly owned treatment works (POTWs) (metal and metal compounds).

g Class I wells, Class II-V wells, and underground injection.

h Resource Conservation and Recovery Act (RCRA) subtitle C landfills; other on-site landfills, land treatment, surface impoundments, other land disposal, other landfills.

i Storage only, solidification/stabilization (metals only), other off-site management, transfers to waste broker for disposal, unknown

j The sum of all releases of the chemical to air, land, water, and underground injection wells.

k Total amount of chemical transferred off-site, including to POTWs.

RF = reporting facilities; UI = underground injection

Source: TRI06 2008 (Data are from 2006)

“Clean” fuels such as natural gas can also produce significant levels of formaldehyde (Dasgupta et al. 2005). In large-bore gas turbine engine exhaust, the ratio of formaldehyde to total hydrocarbons in the exhaust is about 1–2.5%. Exhaust from internal combustion engines powered by sludge digester gas contains formaldehyde levels of 50–200 ppm. Formaldehyde generation is also an issue with the clean power generation technologies of the future. Methanol-based fuel cells, which many regard as ultimately more practical than hydrogen fuel cells, can produce substantial amounts of formaldehyde (Dasgupta et al. 2005).

There is a potential for release of formaldehyde to air from hazardous waste sites. Formaldehyde has been detected in air samples collected at 6 of the 29 hazardous waste sites where formaldehyde has been detected in some environmental media (HazDat 2008).

Some materials used to construct and finish the interiors of new houses emit formaldehyde. The emissions of formaldehyde from these materials can result in substantial contamination of indoor air. In the past, elevated concentrations of formaldehyde in newly manufactured homes were a result of emissions from engineered wood products. An understanding of the problem led to the development of test methods and the establishment of guidelines for the emissions of formaldehyde from wood products by the U.S. Department of Housing and Urban Development. Today, the emissions of formaldehyde from wood products are substantially lower (Hodgson et al. 1999). Specific emission rates of formaldehyde measured in 1997 and 1998 in four newly manufactured homes in Plant City, Florida, several of which had incorporated interior finish materials with lower volatile organic compound (VOC) emissions and one of which had a modified ventilation system, had a median value of 41 μg/m^2^/hour, and all the emission rates measured were <70 μg/m^2^/hour (Hodgson et al. 1999). These emission rates are generally consistent with the formaldehyde emission rates measured for various engineered wood products (Hodgson et al. 1999). Formaldehyde emission rates reported in a study of four new manufactured houses sampled over 2–9.5 months after installation and seven new site built houses sampled 1–2 months after completion in 1997 and 1998 were 29–68 and 10–58 μg/m^2^/hour, respectively (Hodgson et al. 2000). Construction materials that were identified as major sources of formaldehyde included plywood flooring, latex paint, and sheet vinyl flooring. A plywood specimen used in the construction of these houses had an emission rate of 29 μg/m^2^/hour after 72 hours of exposure (Hodgson et al. 2000). In a study measuring emission rates in a new, unoccupied manufactured house in Gaithersburg, Maryland over the course of 1 year (August 2002–September 2003), formaldehyde emission rates ranged from 34 to 121 μg/m^2^/hour (DOE 2004).

Newly manufactured structural insulated panels obtained in March 2003 from two separate manufacturers and measured at 1 and 4 months had formaldehyde emission rates of 4.8 and <3 μg/m^2^/hour, respectively (DOE 2003).

Measured formaldehyde emission rates from low nitrogen oxide-emitting, unflued gas heaters ranged from <0.1 to 2.5 ng/Joule (Brown et al. 2004).

### 5.2.2 Water

Estimated releases of 0.33 million pounds (~150 metric tons) of formaldehyde to surface water and to publicly owned treatment works (POTWs) from 725 domestic manufacturing and processing facilities in 2006 accounted for about 1.5% of the estimated total environmental releases from facilities required to report to the TRI (TRI06 2008). These releases are summarized in Table 5-1.

There is a potential for release of formaldehyde to water from hazardous waste sites. Formaldehyde has been detected in surface water samples collected at 6 of the 29 hazardous waste sites and in groundwater samples collected at 4 of the 29 hazardous waste sites where formaldehyde has been detected in some environmental media (HazDat 2008).

### 5.2.3 Soil

Estimated releases of 0.30 million pounds (~138 metric tons) of formaldehyde to soils from 725 domestic manufacturing and processing facilities in 2006 accounted for about 1.4% of the estimated total environmental releases from facilities required to report to the TRI (TRI06 2008). An additional 11.96 million pounds (~5,426 metric tons), constituting about 56% of the total environmental emissions, were released via underground injection (TRI06 2008). These releases are summarized in Table 5-1.

Formaldehyde may be directly released to soil during agricultural application as a fumigant fungicide or a bactericide (Tomlin 2003).

There is a potential for the release of formaldehyde to soil from hazardous waste sites. Formaldehyde has been detected in soil samples collected at 1 of the 29 hazardous waste sites and in sediment samples collected at 1 of the 29 hazardous waste sites where formaldehyde has been detected in some environmental media (HazDat 2008).

## 5.3 ENVIRONMENTAL FATE

### 5.3.2.1 Air

Formaldehyde reacts with the NO_3_ radical by H-atom extraction with a lifetime of 83 days, assuming a 12-hour average nighttime NO_3_ radical concentration of 5x10^8^ molecules per cm^3^ (Atkinson and Arey 2003).

### 5.3.2.3 Sediment and Soil

The fate of formaldehyde in soil is not fully understood, but it is biodegradable to carbon dioxide and water or formic acid under both aerobic and anaerobic conditions. It is also biologically active, reacting readily with phenol, amine, amide, sulfide, purine, and pyrimidine functional groups, each of which can be found in soil humic substances. Further, formaldehyde is subject to spontaneous polymerization, forming units of paraformaldehyde (Cooke et al. 2003).

In a study investigating chemical interactions with soil humic substances by use of co-elution of radiolabelled compounds with gel filtration chromatography-separated humic substance fractions, results suggested a direct association of free formaldehyde with low molecular weight humic substances (Cooke et al. 2003). This study also suggested that the degree of binding of formaldehyde to the humic substances became more stable over time (Cooke et al. 2003).

## 5.4 LEVELS MONITORED OR ESTIMATED IN THE ENVIRONMENT

### 5.4.1 Air

The main source of formaldehyde in the atmosphere is believed to be photochemical oxidation of hydrocarbon combustion products. As much as 88% of formaldehyde in urban air is thought to be photochemically derived (Austin 2003).

Dasgupta et al. (2005) measured summertime ambient formaldehyde levels in a study of five major U.S. cities: Nashville, Tennessee (June–July 1999); Atlanta, Georgia (August 1999); Houston, Texas (August–September 2000); Philadelphia, Pennsylvania (June–July 2001); and Sydney, Florida (April–June 2002). Reported concentration ranges were 1.43–12.67 ppb (mean 5.05 ppb) in Nashville, 0.42– 18.25 ppb (mean 7.96 ppb) in Atlanta, 0.15–47.13 ppb (mean 4.49 ppb) in Houston, 0.3–3–9.53 ppb (mean 3.12 ppb) in Philadelphia, and 0.37–9.38 ppb (mean 2.63 ppb) in Sydney. It was shown that land-sea breeze circulations played an important role in observed concentrations in coastal cities, and clear diurnal patterns were observed at all the sites (Dasgupta et al. 2005).

Multimedia sampling at a subset of Arizona homes participating in EPA’s National Human Exposure Assessment Survey was conducted in order to assess residential environmental exposure to volatile organic compounds (Gordon et al. 1999). Formaldehyde was found in 69% of the indoor air samples collected, with a median concentration of 17 ppb (21 μg/m^3^) and 21% of the outdoor air samples collected had a median concentration of 5.1 ppb (6.3 μg/m^3^).

The median formaldehyde concentration measured in 1997 and 1998 in four newly manufactured homes in Plant City, Florida, several of which had incorporated interior finish materials with lower VOC emissions and one of which had a modified ventilation system, was reported as 37 ppb, and all the concentrations were <50 ppb (DOE 1999). A mean indoor air formaldehyde concentration of 40 ppb was reported in a study of four new manufactured houses sampled over 2–9.5 months after those houses were installed and of seven new site-built houses sampled 1–2 months after completion in 1997 and 1998 (Hodgson et al. 2000). Formaldehyde concentrations ranged from 21 ppb - 47 ppb in the manufactured houses and from 14 –58 ppb in the site-built houses. Major identified sources of formaldehyde included plywood flooring, latex paint, and sheet vinyl flooring. In a study measuring indoor air in a new, unoccupied manufactured house in Gaithersburg, Maryland over the course of 1 year (August 2002–September 2003), formaldehyde concentrations exhibited temporal variability ranging from 20 ppb -104 ppb (25 – 128 μg/^m^3) with the lowest concentrations occurring in winter months when indoor relative humidity was low (DOE 2004).

In December 2007 and January 2008, CDC tested travel trailers, park models, and mobile homes provided by FEMA as temporary housing to Gulf Coast residents in Louisiana and Mississippi, residents who were displaced by Hurricanes Katrina and Rita. The results showed an average indoor air concentration of 77 ppb, with measured levels ranging from 3 to 590 ppb, a range higher than typical background indoor air concentrations of 10–30 ppb. Formaldehyde levels are generally lower in cooler temperatures and lower humidity; therefore, levels measured in this study are likely to underestimate those that would occur in the summer months (CDC 2008).

Levels of formaldehyde in conventional homes and workplaces housing nonsmokers ranged from 0.03 to 0.06 mg/m^3^ (0.02–0.05 ppm), while it ranged from 0.05 to 0.35 mg/m^3^ (0.04–0.28 ppm) in homes and workplaces containing environmental tobacco smoke (WHO 2000).

### 5.4.2 Water

Synthetic resin-producing industries generate waste water with high levels of organic matter, including formaldehyde as a major component. Formaldehyde has been measured in these waste waters at concentrations ranging from 7 to 2,711 mg/L (Eiroa et al. 2005).

### 5.4.4 Other Environmental Media

Formaldehyde was detected in commercial 2% and fresh whole milk of cows fed on a typical North American dairy diet, with average concentrations of 0.164 and 0.027 mg/kg, respectively (Kaminski et al. 1993). Available data suggest that the highest concentrations of formaldehyde naturally occurring in foods (up to 60 mg/kg) are in some fruits and marine fish (Environment Canada/Health Canada 2001). Maple syrup collected from maple trees that had been implanted with paraformaldehyde to deter bacterial growth in tap holes contained a maximum formaldehyde concentration of 14 mg/kg, whereas syrup from untreated trees had a concentration of <1 mg/kg (Environment Canada/Health Canada 2001). Formaldehyde concentrations of 3.4 and 4.5 mg/kg in brewed coffee and 10 and 16 mg/kg in instant coffee have been reported (Hayashi et al. 1986).

Mansfield et al. (1977) used liquid chromatography to measure formaldehyde as a combustion product in tobacco smoke from six different brands of American filter tip cigarettes. The average amount of formaldehyde by brand ranged from 45.2 to 73.1 μg/ per cigarette and from 5.1 to 8.9 μg/ per puff. Triebig and Zober report that the level of formaldehyde in side stream cigarette smoke is 50 times higher than main stream smoke (Triebig and Zober 1984), while the National Research Council put the value at 5–8 times more formaldehyde in side stream smoke (NRC 1986).

Formaldehyde is sometimes used as a biocide in finger-paints, and it has been detected in finger-paints at concentrations of 441–793 ppm (mg/kg) (Garrigos et al. 2001).

## 5.5 GENERAL POPULATION AND OCCUPATIONAL EXPOSURE

The contribution of various atmospheric environments to the average exposure to formaldehyde is given in Table 5-2 (WHO 2000).

Table 5-2 The Contribution of Various Atmospheric Environments to the Average Exposure to Formaldehyde

Source | mg/day
Air
Outdoor air (10% of time) | 0.002–0.04
Indoor air
Home (65% of time)
Conventional | 0.3–0.6
Mobile home | 1.0
Environmental tobacco smoke | 0.5–3.5
Workplace (25% of time)
Without occupational exposure | 0.2–0.5
With occupational exposure | 8.0
Environmental tobacco smoke | 0.4–2.8
Smoking (20 cigarettes/day) | 0.9–2.0

Source: WHO 2000

In 13 healthy adult volunteers aged 24–50 years old, formaldehyde was detected in all urine samples collected from 9 men and 4 women at background concentrations of 56.85–70.57 and 60.84–144.57 μg/L, respectively (Takeuchi et al. 2007). The median observed formaldehyde levels in the urine of the men and women were 62.10 and 79.30 μg/L, respectively. Formaldehyde was detected at concentrations ranging from 1,230 to 72,729 ppb in exhaled breath samples collected from 344 adult volunteers having a mean age of 61.6 years. The median observed formaldehyde level detected in exhaled breath samples was 4.263 ppb (Moser et al. 2005).

## 5.7 POPULATIONS WITH POTENTIALLY HIGH EXPOSURES

Formaldehyde concentrations in mobile homes may be up to 14 times higher than in conventional homes (Gammage and Hawthorne 1985; Hawthorne et al. 1986). Gulf Coast residents in Louisiana and

Mississippi who were displaced by Hurricanes Katrina and Rita and were provided travel trailers and mobile homes as temporary housing by FEMA have been exposed to higher-than-normal formaldehyde levels. The average indoor air concentration measured in the study of this housing was 77 ppb (CDC 2008).

Smokers and persons who live in a home with a cigarette smoker also may be exposed to higher levels of formaldehyde. Environmental tobacco smoke, which is a combination of diluted sidestream smoke released from a cigarette’s burning end and mainstream smoke exhaled by an active smoker, can contribute 10–25% (0.1–1 mg/day) of the total average indoor exposure to formaldehyde (WHO 1986).

### 5.8.2 Ongoing Studies

The Federal Research in Progress (FEDRIP 2008) database provides additional information obtainable from a few ongoing studies. These studies may fill in some of the data needs identified in Section 6.8.1. The studies are summarized in Table 5-3.

Table 5-3 Ongoing Studies on Formaldehyde

Investigator | Affiliation | Research description | Sponsor
Faloona, Ian C | University of California, Davis | Researchers are conducting a study of gas phase formaldehyde in a forested environment and the photochemical oxidation of hydrocarbons. The goals of this study are to better understand the atmospheric processing of VOCs and their concurrent formaldehyde production. | National Science Foundation
Kretzschmar, Ilona | CUNY City College | This study describes a method for the generation of porous, cylindrical polymer membranes with a uniform catalyst coating that will lead to the development of new material for the separation and decomposition of formaldehyde in indoor air streams. | National Science Foundation
Marotta, Christopher L | Eltron Research, Inc. | Researchers are conducting a study to develop a small, inexpensive sensor for measuring the concentration of formaldehyde in real-time in order to protect workers who encounter formaldehyde in the chemical industry. The aim is also to create a sensor platform that can be readily adapted for indoor air quality or environmental monitoring applications. | NIOSH

CUNY = City University of New York; NIOSH = National Institute for Occupational Safety and Health; VOC = volatile organic compound

Source: FEDRIP 2008

As previously discussed, in the aftermath of Hurricanes Katrina and Rita, the Federal Emergency Management Agency (FEMA) provided travel trailers, park models, and mobile homes to displaced Gulf Coast residents who had lost their homes. Residents of these trailers and mobile homes have raised concerns about air quality in the trailers and the occurrence of respiratory and other symptoms resulting from exposure to formaldehyde. The Centers for Disease Control and Prevention’s (CDC’s) National Center for Environmental Health (NCEH) has been working with FEMA to investigate the health concerns of those living in the trailers and mobile homes and to take action to protect residents’ health. In December 2007 and January 2008, CDC tested travel trailers, park models, and mobile homes provided by FEMA as temporary housing to Gulf Coast residents in Louisiana and Mississippi who were displaced by hurricanes Katrina and Rita (CDC 2008). The study aimed to determine formaldehyde levels in occupied trailers, determine trailer characteristics that could affect formaldehyde levels, and provide information to assist FEMA in deciding whether to relocate residents from FEMA-supplied trailers in the Gulf Coast area. The findings of this study have been addressed in an official CDC Press Release found on the CDC/NCEH Website at http://www.cdc.gov/nceh/ehhe/trailerstudy/residents.htm#final.

A new survey, NHANES IV, is in the process of being conducted by CDC.