# 4 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

## 4.1 PRODUCTION

Production volume of formaldehyde (37% by weight basis) in the United States in 1990, 1995, and 2000 were reported to be 7.5, 8.7, and 10.3 billion pounds, respectively (IARC 2006). From 1995 to 2000, formaldehyde production averaged an annual growth rate of 1.8% per year and was predicted to grow at a rate of 1.0% per year through 2004 (CMR 2001). The estimated total annual formaldehyde capacities in 1998 and 2001 were 11.3 and 12.5 billion pounds, respectively (C&EN 1998; CMR 2001). The annual growth rate of formaldehyde production from 2001 to 2006 was 0.9% per year, and was predicted to grow at a rate of 1.0% per year through 2010 (CMR 2007). The total annual capacity of formaldehyde production (37% solution basis) in the United States in 2007 was 11.9 billion pounds (SRI 2007). Table 4-1 shows capacity and production volumes for selected years between 1960 and 2007.

As of 2007, three manufacturers of formaldehyde were responsible for over 50% of the annual capacity for the United States: Georgia-Pacific Chemicals LLC. (Albany, Oregon; Columbus, Ohio; Conway, North Carolina; Crossett, Arkansas; Grayling, Michigan; Louisville, Mississippi; Lufkin, Texas; Russellville, South Carolina; Taylorsville, Mississippi; and Vienna, Georgia); Celanese Ltd. (Bishop, Texas); and Hexion Specialty Chemicals, Inc. (Baytown, Texas; Demopolis, Alabama; Diboll, Texas; Fayetteville, North Carolina; Fremont, California; Geismar, Louisiana; Hope, Arkansas; La Grande, Oregon; Louisville, Kentucky; Missoula, Montana; Riegelwood, North Carolina; Sheboygan, Wisconsin; South Glens Falls, New York; and Springfield, Oregon) (SRI 2007). In addition to the above facilities, the following companies contributed to the overall U.S. capacity: Capital Resin Corporation (Columbus, Ohio); D.B. Western, Inc. (La Porte, Texas); DuPont (Parkersburg, West Virginia); Dynea USA, Inc. (Andalusia, Alabama; Moncure, North Carolina; Springfield, Oregon; Toledo, Ohio; and Winnfield, Louisiana); GEO Specialty Chemicals, Inc. (Allentown, Pennsylvania); Hercules Inc. (Louisiana, Missouri); Perstorp Polyols, Inc. (Toledo, Ohio); Praxair, Inc. (Geismar, Louisiana); and Solutia Inc. (Alvin, Texas) (SRI 2007).

Table 4-1 U.S. Formaldehyde Capacity and Production

| Million pounds/year
Year | Capacity | Production volume
1960 | 2,449 | 1,870
1965 | 3,556 | 3,106
1970 | Not available | 4,427
1975 | 8,384 | 4,557
1977 | 8,830 | 6,045
1978 | 9,008 | 6,499
1982 | Not available | 4,817
1986 | Not available | 5,549
1990 | 9,700 | 7,500
1992 | 10,080 | 8,280
1995 | Not available | 8,699
1998 | 11,300 | Not available
2000 | Not available | 10,251
2001 | 12,500 | Not available
2007 | 11,900 | Not available

Sources: C&EN 1994, 1998; CMR 2001; Gerberich et al. 1980; IARC 1995, 2006; SRI 1992, 2007

Table 4-2 lists the facilities in each state that manufacture or process formaldehyde, the intended use, and the range of amounts of formaldehyde that are stored on site. The data listed in Table 4-2 are derived from the Toxics Release Inventory (TRI06 2008). Only certain types of facilities were required to report. Therefore, this is not an exhaustive list.

Table 4-2 Facilities that Produce, Process, or Use Formaldehyde

State^a^ | Number of facilities | Minimum amount on site in pounds^b^ | Maximum amount on site in pounds^b^ | Activities and uses^c^
AK | 5 | 100,000 | 9,999,999 | 1, 2, 3, 4, 5, 7, 9
AL | 116 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
AR | 65 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 10, 11, 12, 13, 14
AZ | 17 | 0 | 999,999 | 1, 2, 3, 5, 6, 7, 8, 10, 11, 12
CA | 95 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
CO | 11 | 0 | 9,999 | 1, 2, 5, 6, 7, 10, 11
CT | 42 | 0 | 99,999,999 | 1, 2, 3, 5, 6, 7, 8, 10, 11, 12, 14
DE | 11 | 100 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 10, 11, 12
FL | 34 | 0 | 999,999 | 1, 2, 3, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
GA | 117 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
HI | 1 | 10,000 | 99,999 | 7
IA | 32 | 0 | 499,999,999 | 1, 2, 3, 5, 6, 7, 8, 9, 10, 11, 13, 14
ID | 16 | 0 | 99,999 | 1, 2, 3, 5, 6, 8, 10, 11, 13
IL | 90 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
IN | 69 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 10, 11, 12, 13, 14
KS | 31 | 0 | 9,999,999 | 1, 2, 3, 5, 6, 7, 8, 9, 10, 11, 12, 13
KY | 46 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
LA | 106 | 0 | 10,000,000,000 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
MA | 44 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12
MD | 24 | 0 | 999,999 | 1, 2, 3, 5, 6, 7, 8, 10, 11, 12, 13
ME | 40 | 0 | 999,999 | 1, 2, 3, 5, 6, 7, 8, 11, 12, 13, 14
MI | 104 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
MN | 91 | 0 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
MO | 50 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
MS | 49 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13
MT | 24 | 0 | 9,999,999 | 1, 3, 4, 5, 6, 7, 8, 12, 13
NC | 136 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13
ND | 5 | 1,000 | 99,999 | 2, 3, 10, 11
NE | 9 | 0 | 999,999 | 1, 5, 6, 7, 12, 13
NH | 25 | 0 | 9,999,999 | 1, 2, 3, 5, 6, 7, 8, 10, 11, 12
NJ | 75 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 14
NM | 6 | 100 | 9,999,999 | 1, 3, 4, 6, 7, 8
NV | 2 | 1,000 | 99,999 | 6, 7
NY | 72 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13
OH | 134 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
OK | 39 | 0 | 49,999,999 | 1, 2, 3, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
OR | 99 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
PA | 98 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
PR | 24 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 14
RI | 18 | 100 | 999,999 | 1, 2, 3, 5, 6, 7, 8, 9, 10, 12, 13
SC | 112 | 0 | 999,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
SD | 9 | 0 | 9,999 | 1, 3, 4, 5, 6, 7, 8, 11, 12, 13, 14
TN | 43 | 0 | 9,999,999 | 1, 2, 3, 5, 6, 7, 8, 9, 10, 11, 12, 13
TX | 160 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
UT | 16 | 0 | 999,999 | 1, 3, 5, 6, 7, 8, 10, 11, 12
VA | 78 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
VT | 6 | 100 | 99,999 | 2, 3, 6, 7, 8, 10
WA | 58 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
WI | 96 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
WV | 47 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
WY | 3 | 0 | 99,999 | 1, 2, 3, 5, 7

a Post office state abbreviations used

b Amounts on site reported by facilities in each state

c Activities/Uses: numbers are defined as follows

1. Produce

2. Import

3. Onsite use/processing

4. Sale/Distribution

5. Byproduct

6. Impurity

7. Reactant

8. Formulation Component

9. Article Component

10. Repackaging

11. Chemical Processing Aid

12. Manufacturing Aid

13. Ancillary/Other Uses

14. Process Impurity

Source: TRI06 2008 (Data are from 2006.)

Formaldehyde has been manufactured primarily from methanol since the beginning of the 21^st^ century (Gerberich and Seaman 2004). Because methanol is manufactured from synthesis gas, usually produced from methane, there have been extensive efforts to develop a one-step process that makes formaldehyde directly from methanol by partial oxidation. Although a successful commercial process has not been developed, a wide range of catalysts and oxidation conditions have been studied (Gerberich and Seaman 2004). Following World War II, approximately 20% of the production volume in the United States was manufactured by vapor phase, non-catalytic oxidation of propane and butanes. This nonselective oxidation process produces a variety of coproducts that require a costly and complex separation system, and therefore, the methanol process is preferred (Gerberich and Seaman 2004).

Formaldehyde is also produced in solid form as its cyclic trimer, trioxane, and as its polymer, paraformaldehyde. As a readily available source of formaldehyde for certain applications, paraformaldehyde is prepared commercially by the concentration of aqueous formaldehyde solutions under vacuum in the presence of small amounts of formic acid and metal formates. Trioxane is prepared commercially by strong acid-catalyzed condensation of formaldehyde in a continuous process (IARC 2006). Available information indicates that paraformaldehyde is produced in the United States by three companies and trioxane is produced by two companies (IARC 2006).

## 4.2 IMPORT/EXPORT

In 1999, the import and export volumes were 82 and 21 million pounds, respectively, and in 2000 they were 62 and 18 million pounds, respectively (CMR 2001). In 2005, the import and export volumes were 21 and 27 million pounds, respectively, and in 2006 they were 22 and 31 million pounds, respectively (CMR 2007).

## 4.3 USE

The most extensive use of formaldehyde is in the manufacture of urea-formaldehyde, phenolformaldehyde, melamine-formaldehyde resins, and polyacetal resins (IARC 2006). Formaldehyde-based resins are used as adhesives and as impregnating resins in the manufacture of particle board, fiber board, plywood, furniture, and other wood products. Plywood is the largest market for phenol-formaldehyde resins, and particle board is the largest for urea-formaldehyde resins (Gerberich and Seaman 2004). These resins are also used for the production of curable moulding materials (appliances, electric controls, telephones, wiring services) and as raw materials for surface coatings and controlled release nitrogen fertilizers. Additionally, they are used in the textile, leather, rubber, and cement industries. Further uses are as binders for foundry sand, stonewool, and glasswool mats in insulating materials, abrasive paper, and brake linings (IARC 2006).

Polyacetal plastics produced by polymerization of formaldehyde are incorporated into automobiles to reduce weight and fuel consumption. They are also used in the manufacture of functional components of audio and video electronics equipment (IARC 2006).

Formaldehyde consumption in the United States in 2005 and 2006 was reported as 10.24 and 10.50 billion pounds, respectively, and it is projected to be 10.93 billion pounds in 2010 (CMR 2007). Formaldehyde consumption in 1999 and 2000 was reported as 9.6 and 9.8 billion pounds, respectively (CMR 2001; IARC 2006). This was a slight decrease from the 11.3 and 11.6 billion pounds demand reported for formaldehyde in 1994 and 1995 (C&EN 1995). The decrease was due to the softening of the housing and construction market, a softening that depressed the demand for formaldehyde in urea- and phenol-formaldehyde resins used in particle board and plywood, respectively (CMR 2007). Since these two classes of thermosetting resins account for more than one-third of formaldehyde consumption, the demand for formaldehyde will continue to track the demand in the housing and construction industry (CMR 2001). In 2001, it was reported that the fastest growing formaldehyde market, at about 5% per year, in the United States is in the production of acetylenic chemicals (butanediol), MDI, and acetal resins (CMR 2001). Table 4-3 shows the distribution of formaldehyde use for select periods between 1963 and 2007.

Table 4-3 Distribution of Formaldehyde Production According to Uses in the United States

| Percentage of consumption
| 1963 | 1969 | 1972 | 1977 | 1989 | 1998 | 2001 | 2007
Phenol-formaldehyde resins | 22 | 22 | 26 | 25 | 22 | 19 | 16.5 | 17
Urea-formaldehyde resins | 21 | 25 | 26 | 25 | 25 | 23 | 24 | 22
Acetal resins | 4 | 6 | 7 | 9 | 9 | 11 | 13 | 13
Acetylenics (butanediol) | NA | 2 | 4 | 6 | 11 | 12 | 11 | 9
Melamine resins | 6 | 7 | 6 | 5 | 4 | 4 | 3 | 3
Methylene diisocyanate | NA | NA | NA | NA | 5 | 6 | 7 | 10
Pentaerythritol | 9 | 7 | 7 | 5 | 7 | 5 | 5 | 5
Hexamethylenetetramine | 6 | 9 | 6 | 5 | 6 | 4 | 3 | 3
Fertilizer | 3 | 3 | 4 | NA | 6 | 4 | 3.5 | 3
Trimethylolpropane | NA | 1.1 | 1.5 | NA | NA | NA | NA | NA
Ethylene glycol | 12 | 4 | 0 | 0 | NA | NA | NA | NA
Miscellaneous | 17 | 14 | 12 | 20 | 5 | 12 | 14 | 15

NA = not available

Sources: C&EN 1989, 1998; CMR 2001, 2007; Gerberich and Seaman 1994; Gerberich et al. 1980.

## 4.4 DISPOSAL

Formaldehyde has been treated by use of biofilters, polymer-coated zeolites, and polymeric membrane, but these procedures can be capital- and space-intensive (Cowan et al. 2005). It has been reported that formaldehyde generated in the engineered wood industry can potentially be stripped from an air stream in a fluidized bed containing boiler ash, which can be returned to a boiler to incinerate the formaldehyde.