# 3 CHEMICAL AND PHYSICAL INFORMATION

No updated information.