# 9 REFERENCES

* Cited in text

Aardema MJ, Tsutsui T. 1995. Series: Current issues in mutagenesis and carcinogenesis, No. 59: Sodium fluoride-induced chromosome aberrations in different cell cycle stages. Mutat Res 331:171–172.7666864
*Aardema MJ, Gibson DP, LeBoeuf RA. 1989. Sodium fluoride-induced chromosome aberrations in different stages of the cell cycle: A proposed mechanism. Mutat Res 223:191–203.2500593
Aasenden R, Peebles TC. 1978. Effects of fluoride supplementation from birth on dental caries and fluorosis in teenaged children. Arch Oral Biol 23:111–115.274920
Aasenden R, Moreno EC, Brudevold R. 1973. Fluoride levels in the surface enamel of different types of human teeth. Arch Oral Biol 18:1403–1410.4518760
Abou-Elela SI, Abdelmonem. 1994. Utilization of wastewater from fertilizer industry- A case study. Wat Sci Tech 29(9):169–173.
*Abukurah AR, Moser AM Jr, Baird CL, 1972. Acute sodium fluoride poisoning. JAMA 222:816–817.4677934
ACGIH. 1971. Documentation of the threshold limit values for substances in the workroom air. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 116–117.
ACGIH. 1983–1984. Threshold limit values for chemical substances and physical agents in the work environment. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
ACGIH. 1992. Threshold limit values for chemical substances and biological agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 22–23, 64–65.
*ACGIH. 2000. Documentation of the threshold limit values and biological indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adams DF. 1960. An automatic hydrogen fluoride recorder proposed for industrial hygiene and stack monitoring. Anal Chem 32:1312–1316.
Addy M, Dowell P. 1986. Dentine hypersensitivity: Effect of interactions between metal salts, fluoride, and chlorhexidine on the uptake by dentine. J Oral Rehabil 13:599–605.3467051
Addy M, Mostafa P. 1988. Dentine hypersensitivity: I. Effects produced by the uptake in vitro of metal ions, fluoride and formaldehyde onto dentine. J Oral Rehabil 15:575–585.3236128
Addy M, Mostafa P. 1989. Dentine hypersensitivity: II. Effects produced by the uptake in vitro of toothpaste onto dentine. J Oral Rehabil 16:35–48.2545848
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Afseth J, Ekstrand J, Hagelid P. 1987. Dissolution of calcium fluoride tablets in vitro and bioavailability in man. Scand J Dent Res 95:191–192.3470910
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA.
*Aigueperse J, Mollard P, Devilliers D, 1988. Fluorine compounds, Inorganic. In: Gerhartz W, ed. Ullmann’s encyclopedia of industrial chemistry. 5^th^ ed., Vol A11. Weinheim, Germany: VCH Publishers, 308–348.
Akesson B, Hogstedt B, Skerfving S. 1980. Fever induced by fluorine-containing lubricant on stainless steel tubes. Br J Ind Med 37:307–309.7426482
Akpata ES, Fakiha Z, Khan N. 1997. Dental fluorosis in 12–15-year-old rural children exposed to fluorides from well drinking water in the hail region of Saudi Arabia. Commun Dent Oral Epidemiol 25:324–327.
*Alarcón-Herrera MT, Martin-Dominguez IR, Trejo-Vázquez R, 2001. Well water fluoride, dental fluorosis, and bone fractures in the Guandiana Valley of Mexico. Fluoride 34(2):139–149.
Alary J, Bourbon P, Balsa C, 1981. A field study of the validity of static paper sampling in fluoride pollution surveys. Sci Total Environ 22:11–18.7336199
*Albanese R. 1987. Sodium fluoride and chromosome damage (in vitro human lymphocyte and in vivo micronucleus assays). Mutagenesis 2:497–499.3328040
Alhava EM, Olkkonen H, Kauranen P, 1980. The effect of drinking water fluoridation on the fluoride content, strength and mineral density of human bone. Acta Orthop Scand 51:413–420.7446020
*Al-Hiyassat AS, Elbetieha AM, Darmani H, 2000. Reproductive toxic effects of ingestion of sodium fluoride in female rats. Fluoride 33(2):79–84.
Alshuller AP. 1969. Air pollution. Anal Chem 41:IR–13R.
*Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Anasuya A, Narasinga Rao BS. 1974. Hydroxyproline peptides of urine in fluorosis. Clin Chim Acta 56:121–123.4423286
*Andersen A, Dahlberg BE, Magnus K, 1982. Risk of cancer in the Norwegian aluminum industry. Int J Cancer 29:295–298.7068278
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ II I, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson R, Beard JH, Sorley D. 1980. Fluoride intoxication in a dialysis unit. Morbidity and Mortality Weekly Reports 29:134–136.
Anderson WJ, Anderson JR. 1988. Hydrofluoric acid burns of the hand: Mechanisms of injury and treatment. J Hand Surg 12A:52–57.
Ando M, Tadano M, Yamamoto S, 2001. Health effects of fluoride pollution caused by coal burning. Sci Total Environ 27:107–116.
Angmar-Mansson B, Whitford GM. 1982. Plasma fluoride levels and enamel fluorosis in the rat. Caries Res 16:334–339.6956449
Anonymous. 1963. Sodium fluoride in bone disease. N Eng J Med 269:216–217.
Anonymous. 1969. Inorganic fluorides. Am Ind Hyg Assoc J 30:98–101.
Anonymous. 1970. Hydrogen fluoride and other inorganic fluorides: Methods for the detection of toxic substances in air booklet. London, England: Her Majesty's Office Stationery Office, 19:1–15.
Anonymous. 1972. Can fluoride cause lung cancer? Fluoride 5:169–171.
Anonymous. 1979. Environmental fluoride. Fluoride 12:1–4.
*Aoba T. 1997. The effect of fluoride on apatite structure and growth. Crit Rev Oral Biol Med 8(2):136–153.9167089
Appleton J. 1994. Formation and structure of dentine in the rat incisor after chronic exposure to sodium fluoride. Scanning Microsc 8(3):711–719.7747169
Appleton J. 1995. Changes in the plasma electrolytes and metabolites of the rat following acute exposure to sodium fluoride and strontium chloride. Arch Oral Biol 40(4):265–268.7605252
*Araibi AA, Yousif WH, Al-Dewachi OS. 1989. Effect of high fluoride on the reproductive performance of the male rat. J Biol Sci Res 20:19–30.
Arends J, Christoffersen J. 1990. Nature and role of loosely bound fluoride in dental caries. J Dent Res 69(special issue):601–5.2179320
*Ares J. 1990. Fluoride-aluminum water chemistry in forest ecosystems of central Europe. Chemosphere 21(4–5):597–612.
Ares JO, Villa A, Mondadori G. 1980. Air pollutant uptake by xerophytic vegetation: Fluoride. Environ Exp Bot 20:259–269.
Armstrong WD, Singer L. 1980. Fluoride tissue distribution: Intracellular fluoride concentrations. Proc Soc Exp Biol Med 164:500–506.7413669
*Armstrong WD, Gedalia I, Singer L, 1970. Distribution of fluoride. In: Fluoride and human health. Geneva, Switzerland: WHO Monograph Series 59:93–139.
Arnala I, Alhava EM, Kauranen P. 1985. Effects of fluoride on bone in Finland: Histomorphometry of cadaver bone for low and high fluoride areas. Acta Orthop Scand 56:161–166.4013707
*Arnala I, Alhava EM, Kivivuori R, 1986. Hip fracture incidence not affected by fluoridation. Acta Orthop Scand 57:344–348.3788501
*Arnesen AK M. 1997. Availability of fluoride to plants grown in contaminated soils. Plant Soil 191:13–25.
*Arnow PM, Bland LA, Garcia-Houchins S, 1994. An outbreak of fatal fluoride intoxication in a long-term hemodialysis unit. Ann Intern Med 121:339–344.8042823
Aschengrau A, Zierler S, Cohen A. 1993. Quality of community drinking water and the occurrence of late adverse pregnancy outcomes. Arch Environ Health 48(2):105–113.8476301
*Ast BH, Finn SB, Chase HC. 1951. Newburgh-Kingston caries fluorine study. II. Further analysis of dental findings including the permanent and deciduous dentitions after 4 years of fluoridation. J Am Dent Assoc 42:188–195.14794340
Ast DB, Smith DJ, Wachs B, 1956. Newburgh-Kingston caries-fluorine study: XIV. Combined clinical and roentgenographic dental findings after ten years of fluoride experience. J Am Dent Assoc 52:314–325.13294995
*Attwood D, Blinkhorn AS. 1991. Dental caries in schoolchildren 5 years after fluoridation ceased in South-west Scotland. Int Dent J 41:43–48.2004838
*Aulerich RJ, Napolitano AC, Bursian SJ, 1987. Chronic toxicity of dietary fluorine to mink. J Anim Sci 65:1759–1767.3443590
*Austen KF, Dworetzky M, Farr RS, 1971. A statement on the question of allergy to fluoride as used in the fluoridation of community water supplies. J Allergy 47:347–348.5280563
Avioli LV. 1987. Adjunctive modes of therapy for postmenopausal osteoporosis: Pros and cons. Postgrad Med 14(9):21–27.
*Avorn J, Niessen LC. 1986. Relationship between long bone fractures and water fluoridation. Gerodontics 2:175–179.3468035
Awadia AK, Birkeland JM, Haugejorden O, 2000. An attempt to explain why Tanzanian children drinking water containing 0.2 or 3.6 mg fluoride per liter exhibit a similar level of dental fluorosis. Clin Oral Invest 4:238–244.
Baars AJ, Van Beek, Spierenburg TJ, 1987. Fluoride pollution in a salt marsh: Movement between soil, vegetation, and sheep. Bull Environ Contam Toxicol 39:945–952.3440150
Baars AJ, Van Beek, Spierenburg TJ, 1988. Environmental contamination by heavy metals and fluoride in the Saeftinge salt marsh (the Netherlands) and its effect on sheep. Vet Q 10:90–98.3413975
Baker BB, Morrison JD. 1955. Determination of microgram quantities of fluoride and cyanide by measurement of current from spontaneous electrolysis. Anal Chem 27:1306–1307.
Balazova G. 1971. Effects of long-term fluorine emissions on children's organs. Med Lav 62:202–207.5138071
*Baltazar RF, Mower MM, Funk M. 1980. Acute fluoride poisoning leading to fatal hyperkalemia. Chest 78(4):660–663.33.7418496
Bang S, Voivin G, Gerster JC, 1985. Distribution of fluoride in calcified cartilage of a fluoride-treated osteoporotic patient. Bone 6:207–210.4052272
Barbakow F. 1983. Intake, absorption, and excretion of dietary fluoride. Int J Vitam Nutr Res [Suppl] 25:83–94.
Barber JC, Farr TD. 1970. Fluoride recovery from phosphorous production. Chem Eng Prog 66:56–62.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barnes D, Bellin J, De Rosa C, 1988. Reference dose (RfD): Description and use in health risk assessments. Vol. 1, appendix A: Integrated risk information system supportive documentation. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600/8–86-032a.
*Barnhart WE, Hiller LK, Leonard GL, 1974. Dentifrice usage and ingestion among four age groups. J Dent Res 53(6):1317–1322.4529918
Baud CA, Bang S, Demeurisse C, 1986. Long-term retention of fluoride in the bones of former aluminum workers. Fluoride Res 27:187–191.
Baud CA, Boivin G, Demeurisse C. 1982. Drug-induced skeletal fluorosis. Fluoride 15(2):54–56.
*Baud CA, Lagier R, Boivin G, 1978. Value of the bone biopsy in the diagnosis of industrial fluorosis. Virchows Arch [Pathol Anat] 380(4):283–297.
*Bauer CF, Andren AW. 1985. Emissions of vapor-phase fluorine and ammonia from the Columbia coal-fired power plant. Environ Sci Technol 19:1099–1103.22288758
*Bawden JW, Crenshaw MA, Wright JT, 1995. Consideration of possible biologic mechanisms of fluorosis. J Dent Res 74(7):1349–1352.7560384
Bawden JW, Deaton TG, Crawford BP. 1992a. Fluoride and calcium content of enamel organ, muscle, liver and plasma in rats. Caries Res 26:263–267.1423440
*Bawden JC, Deaton TG, Crenshaw MA. 1987. The short-term uptake and retention of fluoride in developing enamel and bone. J Dent Res 66:1587–1590.3476558
Bawden JW, Deaton TG, Koch GG, 1992b. Fluoride uptake in hard tissues of fetal guinea pigs in response to various dose regimens. Arch Oral Biol 37(11):929–933.1466641
Bawden JW, McLean P, Deaton TG. 1986. Fluoride uptake and retention at various stages of rat molar enamel development. J Dent Res 65:34–38.3455696
*Bayless JM, Tinanoff N. 1985. Diagnosis and treatment of acute fluoride toxicity. J Am Dent Assoc 110:209–211.3856600
Baylink DJ, Bernstein DS. 1967. The effects of fluoride therapy on metabolic bone disease: A histologic study. Clin Orthop 55:51–85.6079753
Beal JF, Rock WP. 1976. Fluoride gels: A laboratory and clinical investigation. Br Dent J 140:307–310.5099
Bednar CM, Kies C. 1991. Inorganic contaminants in drinking water correlated with disease occurrence in Nebraska. Water Resour Bull 27(4):631–635.
*Bell ME, Largent EJ, Ludwig TG, 1970. The supply of fluorine to man. World Health Organization Monograph Series 59:17–74.4987963
Bell RD. 1936. Poisoning by sodium fluoride. Br Med J 1936:886.
Bellack E. 1972. Methods and materials for fluoride analysis. J AWWA 64:62–66.
Bellack E, Schouboe PJ. 1958. Rapid photometric determination of fluoride in water: Use of sodium 2-(p-sulfophenylazo)-1,8-dihydroxynaphthalene-3,6-disulfonate-zirconium lake. Anal Chem 30:2032–2034.
Beltrán-Aguilar ED, Griffin SO, Lockwood SA. 2002. Prevalence and trends in enamel fluorosis in the United States from the 1930’s to the 1980’s. JADA 133:157–165.11868834
*Bennion JR, Franzblau A. 1997. Chemical pneumonitis following household exposure to hydrofluoric acid. Am J Ind Med 31:474–478.9093664
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Bernstein DS, Cohen P. 1967. Use of sodium fluoride in the treatment of osteoporosis. J Clin Endocrinol Metab 27:197–210.6018573
*Bernstein DS, Sadowsky N, Hegsted DM, 1966. Prevalence of osteoporosis in high- and low-fluoride areas in North Dakota. JAMA 198(5):85–90.
*Berry WT C. 1958. A study of the incidence of mongolism in relation to the fluoride content of water. Am J Ment Defic 62:634.13487630
*Bethea RM. 1974. Improvements in colormetric analysis of chlorine and hydrogen fluoride by syringe-sampling technique. Environ Sci Technol 8:587–588.
*Betterton EA. 1992. Henry's law constants of soluble and moderately soluble organic gases: Effects on aqueous phase chemistry. In: Nriagu JO, ed. Gaseous pollutants: Characterization and cycling. New York, NY: John Wiley & Sons, Inc., 1–50.
Beulke SH. 1998. First-aid treatment of dermal exposure to hydrofluoric acid. Aust J Hosp Pharm 28(6):445.
Bezuglaya EY, Shchutskaya AB, Smirnova IV. 1993. Air pollution index and interpretation of measurements of toxic pollutant concentrations. Atmos Environ 27A(5):773–779.
Bhatt A, Gupta VK. 1985. Pollutants: A new reagent for the detection of fluoride. Microchem J 31:322–325.
Bierman HR. 1972. Fluorides in neoplastic disease. Postgrad Med 51:166–173.
Biersteker K, Zielhuis RL, Dirks O, 1977. Fluoride excretion in urine of school children living close to an aluminum refinery in the Netherlands. Environ Res 13:129–134.844454
Biochemical Assay Committee. 1971. Biological monitoring studies: Fluorides. Am Ind Hyg Assoc J 32:274–279.
Birdsong-Whitford NL, Whitford GM, Lecompte EJ. 1987. Acute fluoride toxicity associated with plasma calcium and fluoride levels. Caries Res 21:165–166.
Bishop PA. 1936. Bone changes in chronic fluorine intoxication. Am J Roentgenol Rad Ther 35:577–585.
Bjarnason S, Noren JG, Koch G. 1989. Enamel fluoride and caries in Icelandic children and a comparison of enamel fluoride in Swedish and Icelandic children. Caries Res 23:87–91.2787208
Blodgett DW, Suruda AJ, Crouch BI. 2001. Fatal unintentional occupational poisonings by hydrofluoric acid in the U.S. Am J Ind Med 40:215–220.11494350
*BNA. 2001. Environmental and Safety Library on the Web States and Territories. Bureau of National Affairs, Inc., Washington, D.C. http://www.esweb.bna.com/. May 25, 2001.
*Bobek S, Kahl S, Ewy Z. 1976. Effect of long-term fluoride administration on thyroid hormones level in blood in rats. Endocrinol Exp 10:289–295.1087230
Boeckh-Haebisch EM, Oliveira-Filho M. 1997. Systemic effects of fluoridated water on rats. Arq Biol Technol 40(1):57–68.
Boeuf B. 1977. Automatic analyzer of fluorine in air. Fluoride 10:12–14.
Bohatyrewicz A. 1999. Effects of fluoride on mechanical properties of femoral bone in growing rats. Fluoride 32(2):47–54.
Boink A, Meulenbelt J, Wemer J, 1995. Systemic fluoride poisoning following dermal hydrofluoric acid exposure: Development of an intravenous sodium fluoride infusion model in rats. J Toxicol Cutaneous Ocul Toxicol 14(2):75–87.
*Boivin G, Meunier PJ. 1990. Fluoride and bone: Toxicological and therapeutic aspects. In: Cohen RD, Lewis B, Alberti KGMM, , eds. The metabolic and molecular basis of acquired disease. Philadelphia, PA: Balliere Tindall, 2:34–52.
Boivin G, Chapuy MC, Baud CA, 1988. Fluoride content in human iliac bone: Results in controls, patients with fluorosis, and osteoporotic patients treated with fluoride. J Bone Miner Res 3(5):497–502.3195361
Boivin G, Chavassieux P, Chapuy MC, 1989. Skeletal fluorosis: Histomorphometric analysis of bone changes and bone fluoride content in 29 patients. Bone 10:89–99.2765315
Bompart G, Do phuoc H, Ourbon P. 1983. Action of hydrogen fluoride on dimethylnitrosamine liver metabolism in rats. Toxicol Eur Res 5:273–276.6675213
*Bonjour JP, Caverzasio J, Rizzoli R. 1993. Effect of fluoride on bone cells. Res Clin Forums 15:9–12.
*Borak J, Callan M, Abbott W. 1991. Hazardous materials exposure: Emergency response and patient care. Englewood Cliffs, NJ: Brady Press, 115, 165–166, 228–229, 239.
Bordelon BM, Saffle JR, Morris SE. 1993. Systemic fluoride toxicity in a child with hydrofluoric acid burns. J Trauma 34(3):437–439.8483187
Borke JL, Whitford GM. 1999. Chronic fluoride ingestion decreases ^45^Ca uptake by rat kidney membranes. J Nutr 129:1209–1213.10356089
Boros I, Vegh A, Schaper R, 1984. Fluoride levels in sera and hard tissues of rats consuming fluoride via drinking water. Fluoride 17:183–192.
Borysewicz-Lewicka M, Kobylanska M. 1983. Periodontal disease, oral hygiene and fluoride content of dental deposits in aluminum workers. Fluoride 16:5–10.
Bourbon P, Rioufol C, Levy P. 1984. Relationships between blood urine and bone fluoride levels in guinea-pig after short exposures to hydrogen fluoride. Fluoride 17:124–131.
*Bowden GH W. 1990. Effects of fluoride on the microbial ecology of dental plaque. J Dent Res 69(special issue):653–659.2179326
*Bowden GH W, Odlum O, Nolette N, 1982. Microbial populations growing in the presence of fluoride at low pH isolated from dental plaque of children living in an area with fluoridated water. Infect Immun 36:247–254.7076297
*Bowen HJ M. 1966. Trace elements in biochemistry. 1st ed. New York, NY: Academic Press, 18–184.
*Brambilla E, Belluomo G, Malerba A, 1994. Oral administration of fluoride in pregnant women, and the relation between concentration in maternal plasma and in amniotic fluid. Arch Oral Biol 39(11):991–994.7695513
*Braun J, Stob H, Zober A. 1984. Intoxication following the inhalation of hydrogen fluoride. Arch Toxicol 56:50–54.6517713
*Brewer RF. 1966. Fluorine. In: Chapman HD, ed. Diagnostic criteria for plants and soils. Riverside, CA: Division of Agricultural Science, University of California, 180–195.
Brimblecombe P, Clegg SL. 1989. Erratum. J Atmos Chem 8:95.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: The C.V. Mosby Company, 113–114, 165–166.
*Broomhall J, Kovar IZ. 1986. Environmental pollutants in breast milk. Rev Environ Health 6(1–4):311–337.3321244
Brown MG. 1985. Fluoride exposure from hydrofluoric acid in a motor gasoline alkylation unit. Am Ind Hyg Assoc J 46:662–669.4072910
*Browne TD. 1974. The treatment of hydrofluoric acid burns. J Soc Occup Med 24:80–89.
*Bruns BR, Tytle T. 1988. Skeletal fluorosis: A report of two cases. Orthopedics 11(7):1083–1087.3405908
Bruun C, Thylstrup A. 1984. Fluoride in whole saliva and dental caries experience in areas with high or low concentrations of fluoride in the drinking water. Caries Res 18:450–456.6592047
*Bucher JR, Hejtmancik MR, Toft JD II, 1991. Results and conclusions of the national toxicology program's rodent carcinogenicity studies with sodium fluoride. Int J Cancer 48:733–737.2071234
*Buckingham FM. 1988. Surgery: A radical approach to severe hydrofluoric acid burns: A case report. J Occup Med 30:873–874.3230434
*Budavari S, ed. 2001. The Merck index- An encyclopedia of chemicals, drugs, and biologicals. 13th ed. Whitehouse Station, NJ: Merck and Co., Inc., 4206, 8699.
Buettner W, Karle E. 1974. Chronic toxicity and retention of fluoride in the unilaterally nephrectomized rat. Caries Res 8:359–367.4525802
Bunce HW. 1985. Fluoride in air, grass, and cattle. J Dairy Sci 68:1706–1711.3897305
*Burke WJ, Hoegg UR, Phillips RE. 1973. Systematic fluoride poisoning resulting from a fluoride skin burn. J Occup Med 15:39–41.4684726
*Burnelle JA, Carlos JP. 1990. Recent trends in dental caries in U.S. children and the effect of water fluoridation. J Dent Res 69 (Spec Iss):723–727.2312893
*Burt BA. 1992. The changing patterns of systemic fluoride intake. J Dent Res 71:1228–1237.1607439
*Burt BA, Keels MA, Heller KE. 2000. The effects of a break in water fluoridation on the development of dental caries and fluorosis. J Dent Res 79:761–769.10728978
*Butler JE, Satam M, Ekstrand J. 1990. Fluoride: an adjuvant for mucosal and systemic immunity. Immunol Lett 26:217–220.1707853
Cabello-Tomas ML, West TS. 1969. Kinetochromic spectrophotometry. Talanta 16:781–788.18960578
*Calderon J, Machado B, Navarro M-E, 2000. Influence of fluoride exposure on reaction time and visuospatial organization in children. Epidemiology 11:S153.
Camarasa JG, Serra-Baldrich E, Lluch M, 1993. Contact urticaria from sodium fluoride. Contact Dermatitis 28(5):294.8365132
Camargo JA. 1996. Comparing levels of pollutants in regulated rivers with safe concentrations of pollutants for fishes: A case study. Chemosphere 33(1):81–90.
*Camargo JA. 2003. Fluoride toxicity to aquatic organisms: A review. Chemosphere 50:251–264.12656244
Cameron AC, Widmer RP, eds. 2003. Handbook of pediatric dentistry. Mosby, Elsevier Science, 390–391.
*Candreva F, Dams R. 1981. Determination of gaseous fluoride and chloride emissions in a municipal incinerator. Sci Total Environ 17:155–163.
Capozzi L, Brunetti P, Negri PL, 1967. Enzymatic mechanism of some fluorine compounds. Caries Research 1:69–77.4960801
Cappell MS, Simon T. 1993. Fulminant acute colitis following a self-administered hydrofluoric acid enema. Am J Gastroenterol 88(1):122–126.8420252
Caravati EM. 1988. Acute hydrofluoric acid exposure. Am J Emerg Med 6:143–150.3281684
Carbone PP, Zipkin I, Sokoloff L, 1968. Fluoride effect on bone in plasma cell myeloma. Arch Intern Med 121:120–140.
Carlson CE, Dewey JE. 1971. Environmental pollution by fluorides in Flathead National Forest and Glacier National Park. Washington, DC: U.S. Department of Agriculture, Forest Service.
*Carlson CH, Armstrong WD, Singer L. 1960a. Distribution and excretion of radiofluoride in the human. Proc Soc Exp Biol Med 104:235–239.13855628
Carlson CH, Singer L, Armstrong WD. 1960b. Radiofluoride distribution in tissues of normal and nephrectomized rats. Proc Soc Exp Biol Med 103:418–420.13807752
*Carnow BW, Conibear SA. 1981. Industrial fluorosis. Fluoride 14(4):172–181.
Carotti AA, Kaiser ER. 1972. Concentrations of twenty gaseous chemical species in the flue gas of a municipal incinerator. J Air Pollut Control Assoc 22(4):248–253.5014083
*Carpenter R. 1969. Factors controlling the marine geochemistry of fluorine. Geochim Cosmochim Acta 33:1153–1167.
Carriere D, Bird DM, Stamm JW. 1987. Influence of a diet of fluoride-fed cockerels on reproductive performance of captive American kestrels. Environmental Pollution 46:151–159.15092738
*Caspary WJ, Langenbach R, Penman BW, 1988. The mutagenicity activity of selected compounds at the TK locus: Rodent vs. human cell. Mutat Res 196:61.3292900
*Caspary WJ, Myhr B, Bowers L, 1987. Mutagenic activity of fluorides in mouse lymphoma cells. Mutat Res 187:165–180.3102959
Cassinelli ME. 1986. Laboratory evaluation of silica gel sorbent tubes for sampling hydrogen fluoride. Am Ind Hyg Assoc J 47:219–224.3010691
*Catanese J, Keaveny TM. 1996. Role of collagen and hydroxyapatite in the mechanical behavior of bone tissue. J Bone Miner Res 11:S295.
*Cauley JA, Murphy PA, Riley TJ, 1995. Effects of fluoridated drinking water on bone mass and fractures: the study of osteoporotic fractures. J Bone Min Res 10:1076–1086.
Cavagna G, Locati G, Ambrosi L. 1969. Experimental studies in newborn rats and mice on the supposed capillary-damaging effects of fluorine and fluorine-containing industrial pollutants. Fluoride Quart Rep 2:214–221.
CDC. 1991. Public health service report on fluorine benefits and risks. Centers for Disease Control. JAMA 262:1061–1067.
*CDER. 1991. Dose determination and carcinogenicity studies of sodium fluoride in Crl:CD-1 mice and Crl:CD (Sprague Dawley) BR rats. Center for Drug Evaluation and Research, Carcinogenicity Assessment Committee. In: Review of fluoride: Benefits and risks: Report of the ad hoc subcommittee on fluoride of the committee to coordinate environmental health and related programs. Washington, DC: Department of Health and Human Services, Public Health Service.
*Cecilioni VA. 1972. Lung cancer in a steel city: Its possible relation to fluoride emissions. Fluoride 5:172–181.
CELDS. 1989. Computer-Aided Environmental Legislative Data Systems. University of Illinois, Urbana, IL.
*CEPA. 1996. National ambient air quality objectives for hydrogen fluoride (HF): Science assessment document. Ontario: CEPA/FPAC Working Group on Air Quality Objectives and Guidelines, Canadian Environmental Protection Act.
Cerklewski FL. 1987. Influence of dietary magnesium on fluoride bioavailability in the rat. J Nutr 117:496–500.3572562
Cerklewski FL, Ridlington JW. 1985. Influence of zinc and iron on dietary fluoride utilization in the rat. J Nutr 115:1162–1167.4032063
Cerklewski FL, Ridlington JW, Bills ND. 1986. Influence of dietary chloride on fluoride bioavailability in the rat. J Nutr 116:618–624.3958808
*Chachra D, Turner CH, Dunipace AJ, 1999. The effect of fluoride treatment on bone mineral in rabbits. Calcif Tissue Int 64:345–351.10089229
*Chan K-M, Svancarek WP, Creer M. 1987. Fatality due to acute hydrofluoric acid exposure. J Toxicol Clin Toxicol 25:333–340.3669118
Chan JT, Stark CM, Wild TW, 1992. Influence of vitamins and iron on plasma fluoride levels in rats. Pediatr Dent 14(1):37–40.1502114
Chang CW, Thompson CR. 1964. An improved diffusion method for determining submicrogram amounts of fluoride in biological samples. Microchem J 8:407–414.
*Chan-Yeung M, Wong R, MacLean L, 1983a. Epidemiologic health study of workers in an aluminum smelter in British Columbia, Canada: Effects on the respiratory system. Am Rev Respir Dis 127:465–469.6838051
*Chan-Yeung M, Wong R, Tan F, 1983b. Epidemiologic health study of workers in an aluminum smelter in Kitimat, British Columbia: II. Effects on musculoskeletal and other systems. Arch Environ Health 38:34–40.6830316
Charkes ND, Brookes M, Makler TP Jr. 1979. Studies of skeletal tracer kinetics. II. Evaluation of five-compartment model of [18F] fluoride kinetics in humans. J Nucl Med 20:1150–1157.536775
Charkes ND, Makler PR, Phillips C. 1978. Studies of skeletal tracer kinetics: I. Digital-computer solution of a five-compartment model of [^18^F] fluoride kinetics in humans. J Nucl Med 19:1301–1309.731317
*Chela A, Reig R, Sanz P, 1989. Death due to hydrofluoric acid. Am J Forensic Med Pathol 10:47–48.2929543
Chen PS, Smith FA, Gardner DE, 1956. Renal clearance of fluoride. Proc Soc Exp Biol Med 92:879–883.13370554
*Chen XQ, Machida K, Ando M. 1999. Effects of fluoride aerosol inhalation on mice. Fluoride 332(3):153–161.
Chiazze L Jr, Wolf P, Ference LD. 1986. An historical cohort study of mortality among salaried research and development workers of the Allied Corporation. J Occup Med 28:1185–1188.3783287
*Chiba K, Yoshida K, Tanabe K, 1982. Determination of ultratrace levels of fluorine in water in urine samples by a gas chromatographic/atmospheric pressure helium microwave induced plasma emission spectrometric system. Anal Chem 54:761–764.7091691
*Chiemchaisri Y, Phillips PH. 1963. Effect of dietary fluoride upon magnesium calcinosis syndrome. J Nutr 81:307–311.14100989
*Chilvers C. 1982. Cancer mortality by site and fluoridation of water supplies. J Epidemiol Community Health 36:237–242.7166676
*Chilvers C. 1983. Cancer mortality and fluoridation of water supplies in 35 U.S. cities. Int J Epidemiol 12:397–404.6654558
Chilvers C, Conway D. 1985. Cancer mortality in England (UK) in relation to levels of naturally occurring fluoride in water supplies. J Epidemiol Community Health 39:44–47.3989433
*Chinoy NJ, Patel D. 1998. Influences of fluoride on biological free radicals in ovary of mice and its reversal. Environ Sci 6(3):171–184.
*Chinoy NJ, Sequeira E. 1992. Reversible fluoride induced fertility impairment in male mice. Fluoride 25(2):71–76.
*Chinoy NJ, Sharma A. 1998. Amelioration of fluoride toxicity by vitamins E and D in reproductive functions of male mice. Fluoride 31(4):203–216.
*Chinoy NJ, Sharma A. 2000. Reversal of fluoride-induced alteration in cauda epididymal spermatozoa and fertility impairment in male mice. Environmental Sciences 7(1):29–38.
*Chinoy NJ, Narayana MV, Dalal V, 1995. Amelioration of fluoride toxicity in some accessory reproductive glands and spermatozoa of rat. Fluoride 28(2):75–86.
*Chinoy NJ, Patel BC, Patel DK, 1997. Fluoride toxicity in the testis and cauda epididymis of guinea pig and reversal by ascorbate. Med Sci Res 25(2):97–100.
*Chinoy NJ, Pradeep PK, Sequeira E. 1992. Effect of fluoride ingestion on the physiology of reproductive organs of male rat. J Environ Biol 13(1):55–61.
*Chinoy NJ, Sequeira E, Narayana MV. 1991. Effects of vitamin C and calcium on the reversibility of fluoride-induced alterations in spermatozoa of rabbits. Fluoride 24(1):29–40.
*Chinoy NJ, Sharma M, Michael M. 1993. Beneficial effects of ascorbic acid and calcium on reversal of fluoride toxicity in male rats. Fluoride 26(1):45–56.
*Chinoy NJ, Walimbe AS, Vyas HA, 1994. Transient and reversible fluoride toxicity in some soft tissues of female mice. Fluoride 27(4):205–214.
*Chlebna-Sokol D, Czerwinski E. 1993. Bone structure assessment on radiographs of distal radial metaphysic in children with dental fluorosis. Fluoride 26(1):37–44.
Cholak J, Schafer LJ, Hoffer F. 1952. Results of a five-year investigation of air pollution in Cincinnati. Ind Hyg Occup Med 6:314–325.
*Choubisa SK, Choubisa DK, Joshi SC, 1997. Fluorosis in some tribal villages of Dungarpur District of Rajasthan, India. Fluoride 30(4):223–228.
*Chow LC. 1990. Tooth-bound fluoride and dental caries. J Dent Res 69(special issue):595–600.2179319
Christie DP. 1980. The spectrum of radiographic bone changes in children with fluorosis. Radiology 136:85–90.7384528
Chubb C. 1985. Reproductive toxicity of fluoride. 3rd International Congress of Andrology, Boston, Massachusetts. J Androl 6:59.
Cimasoni G. 1966. Inhibition of cholinesterase by fluoride in vitro. Biochem J 99:133–137.6007454
Cittanova L, Lelongt B, Verpont C, 1996. Fluoride ion toxicity in human kidney collecting duct cells. Anesthesiology 84:428–435.8602675
Clark R. 1981. Neutrophil iodination reaction induced by fluoride: Implications for degranulation and metabolic activation. Blood 57:913–921.7214022
*Clarkson BH, Fejerskov O, Ekstrand J, 1996. Rational use of fluorides in caries control. In: Fejerskov O, Ekstrand J, Burt BA, eds. Fluorides in dentistry. 2nd ed. Copenhagen: Munksgaard, 347–357.
Clement JG, Filbert M. 1983. Antidote effect of sodium fluoride against organophosphate poisoning in mice. Life Sci 32:1803–1810.6835011
Clements RL, Sergeant GA, Webb P. 1971. Determination of fluorine in rocks and minerals by a pyrohydrolytic method. Analyst 96:51–54.
Clemmesen J. 1983. The alleged association between artificial fluoridation of water supplies and cancer: A review. Bull WHO 61:871–833.6360403
*Clewell HJ II I, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
CLPSD. 1988. Contract Laboratories Program Statistical Database. Washington, DC: U.S. Environmental Protection Agency.
*CMR. 2002. Chemical profile. Hydrofluoric acid. Chemical Market Reporter. October 7, 2002.
Cohen-Solal ME, Augry F, Mauras Y. 2002. Fluoride and strontium accumulation in bone does not correlate with osteoid tissue in dialysis patients. Nephrol Dial Transplant 17:449–454.11865091
*Cohn PD. 1992. An epidemiologic report on drinking water and fluoridation. Environmental Health Service. New Jersey Department of Health.
*Colborn T, Clement C. 1992. Chemically induced alterations in sexual and functional development. The Wildlife/Human Connection. In: Advances in modern environmental toxicology. Volume XXI. Princeton, NJ: Princeton Scientific Publishing Co.
*Cole J, Muriel WJ, Bridges BA. 1986. The mutagenicity of sodium fluoride to L5178Y (wild-type and TK- positive/negative (3.7.2c) mouse lymphoma cells. Mutagenesis 1:157–168.3333272
*Collings GH, Fleming RB L, May R. 1951. Absorption and excretion of inhaled fluorides. AMA Arch Ind Hyg Occup Med 4:585–590.14877318
*Collings GH, Fleming RB L, May R, 1952. Absorption and excretion of inhaled fluorides: Further observations. Ind Hyg Occup Med 6:368–373.
*Collins TF X, Sprando RL, Black TN, 2001a. Developmental toxicity of sodium fluoride measured during multiple generations. Food Chem Toxicol 39:867–876.11434994
*Collins TF X, Sprando RL, Black TN, 2001b. Multigenerational evaluation of sodium fluoride in rats. Food Chem Toxicol 39:601–613.11346491
*Collins TF X, Sprando RL, Shackelford ME, 1995. Developmental toxicity of sodium fluoride in rats. Food Chem Toxicol 33(11):951–960.7590543
Colquhoun J. 1984. Disfiguring dental fluorosis in Aukland, New Zealand. Fluoride 17(4):234–242.
*Colquhoun J. 1992. Fluoridation and fractures. N Z Med J 105(944):436.
*Cook HA. 1969. Fluoride in tea. Lancet 2:329.4184252
Cooke JA, Johnson MS, Davison AW. 1976. Determination of fluoride in vegetation: A review of modern techniques. Environmental Pollution 11:257–268.
*Cooper C, Wickham C, Lacey RF, 1990. Water fluoride concentration and fracture of the proximal femur. J Epidemiol Community Health 44:17–19.2348142
*Cooper C, Wickham CA C, Barker DJ R, 1991. Water fluoridation and hip fracture. JAMA 266:513–514.2061972
Costa JL, Joy DC, Maher DM, 1978. Fluorinated molecule as a trace: Difluoroserotonin in human platelets mapped by electron energy-loss spectroscopy. Science 200:537–539.644312
*Cotton FA, Wilkinson G, Murillo CA, 1999. Advanced inorganic chemistry, 6th ed. New York: John Wiley & Sons, Inc., 62–64.
*CPSC. 2001. Final rule. U.S. Consumer Product Safety Commission. Code of Federal Regulations. 16 CFR 1700. http://cpsc.gov/businfo/frnotices/fr-98/fluoride.html. March 27, 2001.
Craggs C, Davison AW. 1985. The effect of simulated rainfall on grass fluoride concentrations. Environmental Pollution (Series B) 9:309–318.
Craggs C, Blakemore J, Davison AW. 1985. Seasonality in the fluoride concentrations of pasture grass subject to ambient airborne fluorides. Environmental Pollution (Series B) 9:163–178.
Crissman JW, Maylin GA, Krook L. 1980. New York state and U.S. federal fluoride pollution standards do not protect cattle health. Cornell Vet 70:183–192.7408498
Crosby ND, Shepherd PA. 1957. Studies on patterns of fluid intake: Water balance and fluoride retention. Med J Aust 10:341–346.
Cumpston AG, Dinman BD. 1965. A modified diffusion method for the determination of urinary fluoride. Am Ind Hyg Assoc J 26:461–464.
Curry AS. 1962. Twenty-one uncommon cases of poisoning. Br Med J 5279:687–689.
Czerwinski E, Lankosz W. 1977a. Fluoride-induced changes in 60 retired aluminum workers. Fluoride 10:125–136.
Czerwinski E, Lankosz W. 1977b. Gastric ulcer and fluoride. Fluoride 10:149–151.
*Czerwinski E, Nowak J, Dabrowksa D, 1988. Bone and joint pathology in fluoride-exposed workers. Arch Environ Health 43:340–343.3178291
Czerwinski E, Pospulka W, Nowacki G, 1981. Effect of fluoride after discontinuation of occupational exposure. Fluoride 14:61–68.
*Dabeka RW, McKenzie AD. 1981. Microdiffusion and fluoride-specific electrode determination of fluoride in infant foods: Collaborative study. J Assoc Off Anal Chem 64:1021–1026.7275888
*Dabeka RW, McKenzie AD. 1987. Lead, cadmium, and fluoride levels in market milk and infant formulas in Canada. J Assoc Off Anal Chem 70:754–757.3624190
*Dabeka RW, McKenzie AD. 1995. Survey of lead, cadmium, fluoride, nickel, and cobalt in food composites and estimation of dietary intakes of these elements by Canadians in 1986–1988. J AOAC Int 78(4):897–909.7580328
Dabeka RW, Karpinski KF, McKenzie AD, 1986. Survey of lead, cadmium, and fluoride in human milk and correlation of levels with environmental and food factors. Food Chem Toxicol 24:913–921.3781438
*Dabeka RW, McKenzie AD, Lacroix GM A. 1987. Dietary intakes of lead, cadmium, arsenic and fluoride by Canadian adults: A 24-hour duplicate diet study. Food Addit Contam 4(1):89–102.3556679
*Dadej N, Kosiminder K, Machoy Z, 1987. Case history of acute poisoning by sodium fluorosilicate. Fluoride 20(1):11–13.
Daessler HG. 1971. The effect of hydrogen fluoride and cryolite dust upon plants and animals near a hydrogen fluoride factory. Fluoride Quarterly Report 4:21–24.
Dahlgren BE. 1979. Fluoride concentrations in urine of delivery ward personnel following exposure to low concentrations of methoxyflurane. J Occup Med 21:624–626.490224
Daijei H, Chongwan Z. 1988. Radiological and histological studies on bones of experimental rabbits in skeletal fluorosis. Fluoride 21:76–81.
*Dalbey W, Dunn B, Bannister R, 1998a. Acute effects of 10-minute exposure to hydrogen fluoride in rats and derivation of a short-term exposure limit for humans. Regul Toxicol Pharmacol 27:207–216.9693073
*Dalbey W, Dunn B, Bannister R, 1998b. Short-term exposures of rats to airborne hydrogen fluoride. J Toxicol Environ Health 55(4):241–275.
*Dale RH. 1951. Treatment of hydrofluoric acid burns. Br Med J 1:728–732.14821516
*Danchik RS, Millegass HF, Tarcy GP. 1980. The continuous measurement of gaseous fluoride in ambient air. Light Metals 783–799.
*Danielson C, Lyon JL, Egger M, 1992. Hip fractures and fluoridation in Utah's elderly population. JAMA 268:746–748.1640574
Darmer KI Jr., Haun CC, MacEwen JD. 1972. The acute inhalation toxicology of chlorine pentafluorine. Am Ind Hyg Assoc J 33:661.4634104
Das TK, Susheela AK. 1991a. Chronic fluoride toxicity and pituitary-adrenal function. Environ Sci 1(2):57–62.
Das TK, Susheela AK. 1991b. Effect of chronic fluoride toxicity on glucocorticoid level in plasma and urine. Fluoride 24(1):23–28.
Das TK, Susheela AK. 1993. Effect of long-term administration of sodium fluoride on plasma calcium level in relation to intestinal absorption and urinary excretion in rabbits. Environ Res 62:14–18.8325259
Das TK, Susheela AK, Gupta IP, 1994. Toxic effects of chronic fluoride ingestion on the upper gastrointestinal tract. J Clin Gastroenterol 18(3):194–199.8034913
Dasarathy S, Das TK, Gupta IP, 1996. Gastroduodenal manifestations in patients with skeletal fluorosis. Gastroenterology 31(3):333–337.
Daston GP, Rehnberg BF, Carver B, 1985. Toxicity of sodium fluoride to the postnatally developing rat kidney. Environ Res 37:461–474.4017997
*Davis WL. 1972. Ambient air fluorides in Salt Lake County. Rocky Mountain Med J 69:53–56.
Davydova VI, Pochashev EN. 1974. The combined effect of manganese and fluorine compounds on the body. Gig Sanit 7:21–25.
*Dayal HH, Brokwick M, Morris R, 1992. A community-based epidemiologic study of health sequelae of exposure to hydrofluoric acid. Ann Epidemiol 2(3):213–230.1342272
*Dean HT. 1934. Classification of mottled enamel diagnosis. J Am Dent Assoc 21:1421–1426.
*Dean HT. 1938. Endemic fluorosis and its relation to dental caries. Public Health Reports 53:1443–1452.19315674
*Dean HT, Arnold FA Jr, Jay P, 1950. Studies on mass control of dental caries through fluoridation of the public water supply. Public Health Rep 65:1403–1408.14781280
*Dean HT, Dixon RM, Cohen C. 1935. Mottled enamel in Texas. Public Health Rep 50:424–42.
*Dean HT, Jay P, Arnold FA Jr, 1939. Domestic water and dental caries, including certain epidemiological aspects of L. acidophilus. Public Health Rep 54:862–868.
*Dean HT, Jay P, Arnold FA Jr, 1941. Domestic water and dental caries. II. A study of 2,832 white children aged 12–14 years of age with suburban Chicago communities, including L. acidophilus studies of 1,761 children. Public Health Rep 56:761–792.
*Dean HT, Jay P, Arnold FA Jr, 1942. Domestic water and dental caries. V. Additional studies of the relation of fluoride domestic waters to dental caries experience in 4,425 white children, aged 2 to 14 years of 13 cities in four states. Public Health Rep 57:1155–1179.19315881
DeChatelet LR, Campbell TL, Westrick MA, 1981. Effects of fluoride on the oxidative metabolism of human neutrophils. Biochem Med 25:106–113.6261736
Deka RC, Kacker SK, Shambaugh GE Jr. 1978. Intestinal absorption of fluoride preparations. Laryngoscope 88:1918–1921.732493
*DeLiefde B. 1998. The decline of caries in New Zealand over the past 40 years. NJ Dent J 94:109–113.
*DeLopez OH, Smith FA, Hodge HC. 1976. Plasma fluoride concentrations in rats acutely poisoned with sodium fluoride. Toxicol Appl Pharmacol 37:75–83.968908
*de Moraes Flores EM, Martins AF. 1997. Distribution of trace elements in egg samples collected near coal power plants. J Environ Qual 26:744–748.
*DenBesten PK. 1994. Dental fluorosis: Its use as a biomarker. Adv Dent Res 8:105–110.7993553
DenBesten PK, Crenshaw MA. 1984. The effects of chronic high fluoride levels on forming enamel in the rat. Arch Oral Biol 29:675–679.6594099
*DenBesten PK, Thariani H. 1992. Biological mechanisms of fluorosis and level and timing of systemic exposure to fluoride with respect to fluorosis. J Dent Res 71(5):1238–1243.1607440
*Derelanko MJ, Gad SC, Gavigan F, 1985. Acute dermal toxicity of dilute hydrofluoric acid. Journal of Toxicology-Cutaneous and Ocular Toxicology 4:73–85.
Derner HA. 1967. Semi-automated determination of fluoride in urine. Am Ind Hyg Assoc J 28:357–362.4292816
*Derryberry OM, Bartholomew MD, Fleming RB L. 1963. Fluoride exposure and worker health. Arch Environ Health 6:503–514.14027180
Desai VK, Bhavsar BS, Mehta NR, 1983. Clinical radiological observations among workers of fluoride processing industry. Fluoride 16:90–100.
DeTroiani RM, Sanchez TM, Lavado RS. 1987. Soil response and alfalfa fluoride content as affected by irrigation water. Fluoride 20:14–17.
Deutsch D, Gedalia I. 1982. Fluoride concentration in human fetal enamel. Caries Res 16:428–432.6959694
*deVilliers AJ, Windish JP. 1964. Lung cancer in a fluorspar mining community: I. Radiation, dust and mortality experience. Br J Ind Med 21:94–109.14142524
Dewey JE. 1973. Accumulation of fluorides by insects near an emission source in western Montana. Environ Entomol 2:179–182.
*DHHS. 1991. Review of fluoride: Benefits and risks: Report of the ad hoc subcommittee on fluoride of the committee to coordinate environmental health and related programs. Washington, DC: Department of Health and Human Services, Public Health Service.
*DHHS. 2000. Oral Health in America: A Report of the Surgeon General. Rockville, MD: U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research, National Institutes of Health.
DHHS. 2001a. Oral health. Healthy people 2010. Washington, DC: U.S. Department of Health and Human Services, Office of Disease Prevention and Health Promotion. http://www.health.gov/healthypeople.
*DHHS. 2001b. Recommendations for using fluoride to prevent and control dental caries in the United States. MMWR 50(RR-14):1–42. http://www.cdc.gov/mmwr/preview/mmwrhtml/rr5014al.htm.
Dhuna AK, Gu XF, Pascual-Leone A, 1992. Skeletal fluorosis: An unusual cause of progressive radiculomyelopathy. Spine 17(7):842–844.1380185
*Dibbell DG, Iverson RE, Jones W, 1970. Hydrofluoric acid burns of the hand. J Bone Joint Surg 52:931–936.5479482
*Dieffenbacher PF, Thompson JH. 1962. Burns from exposure to anhydrous hydrofluoric acid. J Occup Med 4:325–326.13886248
*Dinman BD, Backenstos DL, Carter RP, 1976a. A five year study of fluoride absorption and excretion. J Occup Med 18:17–20.1249652
*Dinman BD, Bovard WJ, Bonney TB, 1976b. Excretion of fluoride during a seven-day workweek. J Occup Med 18:14–16.1249651
*Dinman BD, Elder MJ, Bonney TB, 1976c. A 15-year retrospective study of fluoride excretion and bony radiopacity among aluminum smelter workers - part 4. J Occup Med 18:21–23.1249653
Di Stefano CM, Ruggien M. 1969. Interaction of fluorine with serum albumin. Fluoride Quarterly Report 2:91–96.
DOE. 1992. Chemical contaminants on DOE lands and selection of contaminant mixtures for subsurface science research. Washington, DC: National Technical Information Service, U.S. Department of Energy. NTIS DE92–014826.
*Doll R, Kinlen L. 1977. Fluoridation of water and cancer mortality in the U.S.A. Lancet 1:1300–1302.68395
Dost FN. 1970. Fluorine distribution in rats following acute intoxication with nitrogen and halogen fluorides and with sodium fluoride. Toxicol Appl Pharmacol 17:573–584.5495982
*DOT. 2001. List of hazardous substances and reportable quantities. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.101, Appendix A. http://www.dot.gov/safety.html. March 26, 2001.
*Dousset JC, Rioufol C, Feliste R, 1984. Effects of inhaled HF on lipid metabolism in guinea pigs. Fundam Appl Toxicol 4:618–623.6479508
Dousset JC, Rioufol C, Philibert C, 1987. Effects of inhaled HF on cholesterol carbohydrate and tricarboxylic acid metabolism in guinea-pigs. Fluoride 20:137–141.
Dowbak G, Rose K, Rohrich RJ. 1994. A biochemical and histologic rationale for the treatment of hydrofluoric acid burns with calcium gluconate. J Burn Care Rehab 15:323–327.
Doyle JJ. 1979. Toxic and essential elements in bone: A review. J Anim Sci 49:482–497.389915
Drinkard CR, Deaton TG, Bawden JW. 1985. Enamel fluoride in nursing rats with mothers drinking water with high fluoride concentrations. J Dent Res 64:877–880.3858313
Driscoll WS. 1981. A review of clinical research on the use of prenatal fluoride administration for prevention of dental caries. ASDC J Dent Child 48:109–117.7012207
*Driscoll WS, Horowitz HS, Meyers RJ, 1986. Prevalence of dental caries and dental fluorosis in areas with negligible, optimal, and above-optimal fluoride concentrations in drinking water. Corrections. J Am Dent Assoc 113:370.
Dubois L, Monkman JL, Teichman T. 1962. The determination of urinary fluorides. Am Ind Hyg Assoc J 23:157–163.13888065
Duffey PH, Tretbar HC, Jarkowski TL. 1971. Giant cells in bone marrow of patients on high-dose fluoride treatment. Ann Intern Med 75:745–757.5122161
Dunipace AJ, Brizendine EJ, Wilson ME, 1998. Chronic fluoride exposure does not cause detrimental, extraskeletal effects in nutritionally deficient rats. J Nutr 128:1392–1400.9687561
Dunipace AJ, Brizendine EJ, Zhang W, 1995. Effect of aging on animal response to chronic fluoride exposure. J Dent Res 74(1):358–368.7876430
*Dunipace AJ, Zhang W, Noblitt TW, 1989. Genotoxic evaluation of chronic fluoride exposure: Micronucleus and sperm morphology studies. J Dent Res 68:1525–1528.2584520
*Dunn BJ, Mackinnon MA, Knowlden NF, 1992. Hydrofluoric acid dermal burns. J Occup Med 34(9):902–909.1447596
Duxbury AJ, Leach FN, Duxbury JT, 1982. Acute fluoride toxicity. Br Dent J 153:64–66.7052108
Eanes ED, Reddi AH. 1979. The effect of fluoride on bone mineral apatite. Metab Bone Dis Relat Res 2:3–10.
Ebeling W, Reierson DA, Wagner RE. 1968. The influence of repellency on the efficacy of blatticides: III. Field experiments with German cockroaches with notes on three other species. J Econ Entomol 61:751.
Eckerlin RG, Maylin GA, Krook L. 1986. Milk production of cows fed fluoride contaminated commercial feed. Cornell Vet 76:403–414.3757523
Edelman P. 1986. Hydrofluoric acid burns. State of the Art Reviews: Occupational Medicine 1:89–103.3299779
Edgar WM. 1981. Fluoride metabolism in dental plaque, bacteria and man. Front Oral Physiol 3:19–37.
*Ehrnebo M, Ekstrand J. 1986. Occupational fluoride exposure and plasma fluoride levels in man. Int Arch Occup Environ Health 58:179–190.3770957
*Eichler HG, Lenz K, Fuhrmann M, 1982. Accidental ingestion of NaF tablets by children. Int J Clin Pharmacol Ther Toxicol 20:334–338.7107087
*Einfeld W, Horstman SW. 1979. Investigation of a dual filter sampling method for gaseous and particulate fluoride. Am Ind Hyg Assoc J 40:626–632.484486
*Eklund SA, Burt BA, Ismail AI, 1987. High-fluoride drinking water, fluorosis, and dental caries in adults. J Am Dent Assoc 114(3):324–328.3470353
*Ekstrand J. 1977. Fluoride concentrations in saliva after single oral doses and their relation to plasma fluoride. Scand J Dent Res 85:16–17.265079
*Ekstrand J. 1978. Relationship between fluoride in the drinking water and the plasma fluoride concentration in man. Caries Res 12:123–127.272948
Ekstrand J. 1989. Fluoride intake in early infancy. J Nutr 119:1856–1860.2693648
*Ekstrand J, Ehrnebo M. 1979. Influence of milk products on fluoride bioavailability in man. Eur J Clin Pharmacol 16:211–215.499322
*Ekstrand J, Ehrnebo M. 1983. The relationship between plasma fluoride, urinary excretion rate, and urine fluoride concentrations in man. J Occup Med 25:745–748.6631559
Ekstrand J, Koch G. 1980. Systemic fluoride absorption following fluoride gel application. J Dent Res 59:1067.6929293
*Ekstrand J, Whitford GM. 1984. Fluoride in body fluids-cariostatic and toxicologic aspects. In: Guggenheim B, ed. Cariology today. International Congress, Zürich 1983. 269–278.
Ekstrand J, Alván G, Boréus LO, 1977a. Pharmacokinetics of fluoride in man after single and multiple oral doses. Eur J Clin Pharmacol 12:311–317.590317
*Ekstrand J, Boreus LO, de Chateau P. 1981c. No evidence of transfer of fluoride from plasma to breast milk. Br J Med 283:761–762.
*Ekstrand J, Ehrnebo M, Boréus LO. 1978. Fluoride bioavailability after intravenous and oral administration: Importance of renal clearance and urine flow. Clin Pharm Ther 23:329–337.
Ekstrand J, Ehrnebo M, Whitford GM, 1980b. Fluoride pharmacokinetics during acid-base balance changes in man. Eur J Clin Pharmacol 18:189–194.7428802
*Ekstrand J, Ericsson Y, Rossell S. 1977b. Absence of protein-bound fluoride from human blood plasma. Arch Oral Biol 22:229–232.270313
*Ekstrand J, Fomon SJ, Ziegler EE, 1994a. Fluoride pharmacokinetics in infancy. Pediatr Res 35(2):157–163.8165049
*Ekstrand J, Hardell LI, Spak CJ. 1984a. Fluoride balance studies on infants in a 1 ppm water fluoride area. Caries Res 18:87–92.6580961
Ekstrand J, Koch G, Lindgren LE, 1981a. Pharmacokinetics of fluoride gels in children and adults. Caries Res 15:213–220.
*Ekstrand J, Koch G, Petersson LG. 1980a. Plasma fluoride concentration and urinary fluoride excretion in children following application of the fluoride-containing varnish Duraphat. Caries Res 14:185–189.6929729
*Ekstrand J, Koch G, Petersson LG. 1983. Plasma fluoride concentrations in pre-school children after ingestion of fluoride tablets and toothpaste. Caries Res 17:379–384.6575874
Ekstrand J, Lange A, Ekberg O, 1981b. Relationship between plasma, dentin, and bone fluoride concentrations in rats following long-term fluoride administration. Acta Pharmacol Toxicol 48:433–437.
*Ekstrand J, Spak CJ, Ehrnebo M. 1982. Renal clearance of fluoride in a steady state condition in man: Influence of urinary flow and pH changes by diet. Acta Pharmacol Toxicol 50:321–325.
*Ekstrand J, Spak C-J, Flach J, 1984b. Distribution of fluoride to human breast milk following intake of high doses of fluoride. Caries Res 18:93–95.6580962
*Ekstrand J, Ziegler EE, Nelson SE, 1994b. Absorption and retention of dietary and supplemental fluoride by infants. Adv Dent Res 8(2):175–180.7865072
Elfers LA, Decker CE. 1968. Determination of fluoride in air and stack gas samples by use of an ion specific electrode. Anal Chem 40:1658–1661.5747332
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier Science Publishing Company, Inc., 76, 83, 531–536, 873–874, 924–929.
Elrashidi MA, Lindsay WL. 1987. Effect of fluoride on pH, organic matter and solubility of elements in soils. Environ Pollut 47:123–134.15092714
Elsaadi MS, Hall AH, Hall PK, 1989. Hydrofluoric-acid dermal exposure. Vet Hum Toxicol 31:243–247.2741315
Elsair RM J, Denine R, Reggabi M, 1980. Boron as a preventive antidote in acute and subacute fluoride intoxication in rabbits: Its action on fluoride and calcium-phosphorus metabolism. Fluoride 13:129–138.
EPA. 1971. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.142.
*EPA. 1975. Standards of performance for the phosphate fertilizer industry. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.1200–60.243.
EPA. 1978. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1979. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 143.3.
*EPA. 1980a. Reviews of the environmental effects of pollutants: IX. Fluoride. Cincinnati, OH: Health Effects Research Laboratory, Office of Research and Development, U.S. Environmental Protection Agency. EPA-600/1–78-050.
*EPA. 1980b. Standards of performance for primary aluminum reduction plants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.190–60.194.
EPA. 1985a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.51.
EPA. 1985b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.62.
EPA. 1985c. U.S. Environmental Protection Agency. Federal Register 50(220):47142–47155.
EPA. 1986. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
EPA. 1987. U.S. Environmental Protection Agency. Federal Register 52:21152–21208.
EPA. 1988. Test results of acute inhalation studies with anhydrous hydrogen fluoride with cover letter dated 03/16/88. Washington, DC: U.S. Environmental Protection Agency. FYI-OTS-0388–0607.
EPA. 1990. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency. Office of Health and Environmental Assessment. EPA 600/8–88/066F.
EPA. 1994. Method 9056. Determination of inorganic anions by ion chromatography. Environmental Protection Agency. Office of Solid Waste and Emergency Response. http://www.epa.gov/epaoswer/hazwaste/test/9056.pdf. September 16, 1995.
*EPA. 1996. Method 9214. Potentiometric determination of fluoride in aqueous samples with ion-selective electrode. Environmental Protection Agency, Office of Solid Waste and Emergency Response. http://www.epa.gov/epaoswer/hazwaste/test/9214.pdf. November 6, 1996.
*EPA. 1997. EPA Environmental monitoring methods index. McLean, VA: Enviro Dynamics.
*EPA. 1998a. AP-42 Section 1.1. Bituminous and subbituminous coal combustion. http://www.epa.gov/ttnchie1/ap42/ch01/final/c01s01.pdf. September 1998.
*EPA. 1998b. Background Report: AP-42 Section 12.1. Primary aluminum. http://www.epa.gov/ttnchie1/ap42/ch12/bgdocs/b12s01.pdf. November 12, 1998.
*EPA. 1998c. National environmental methods index. EPA methods 340.1, 340.2, and 340.3. U.S. Environmental Protection Agency. http://reports.er.usgs.gov/dev60cgi/rwcgi60?
*EPA. 2000. Taking toxics out of the air: Progress in setting “maximum achievable control technology” standards under the Clean Air Act. http://www.epa.gov/oar/oaqps/takingtoxics/ October 03, 2003.
*EPA. 2001a. Accidental release prevention. Table of toxic endpoints. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68, Appendix A. http://ecfrback.access.gpo.gov/otcg...=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001b. Accidental release prevention. Threshold quantity. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68.130. http://ecfrback.access.gpo.gov/otcg...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001c. BPT effluent limitations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 415.82. http://ecfrback.access.gpo.gov/otcgi/cf...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001d. Contaminated soil. Alternative LDR treatment standards for contaminated soil. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.49. http://ecfrback.access.gpo.gov/otcg...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001e. Effluent limitations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 422.42. http://ecfrback.access.gpo.gov/otcgi/cf...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001f. Groundwater protection standards at inactive uranium processing sites. Listed constituent. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 192, Appendix I. http://ecfrback.access.gpo.gov/otcgi/cf...=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001g. Hazardous waste. Health based limits for exclusion of waste-derived-residue. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266, Appendix VII. http://ecfrback.access.gpo.gov/otcgi/cf...=BAPPCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001h. Hazardous waste. Identification and listing. Fluorine. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33 (e). http://ecfrback.access.gpo.gov/otcgi/cf...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001i. Hazardous waste. Identification and listing. Hydrogen fluoride. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33 (f). http://ecfrback.access.gpo.gov/otcgi/cf...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001j. National primary drinking water regulations. Maximum contaminant level goals for inorganic contaminants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.51 (b). http://ecfrback.access.gpo.gov/otcgi/cfr/otfil. March 26, 2001.
*EPA. 2001k. National primary drinking water regulations. Maximum contaminant levels for inorganic contaminants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.62 (b). http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter. March 26, 2001.
*EPA. 2001l. National secondary drinking water regulations. Secondary maximum contaminant levels. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 143.3. http://ecfrback.access.gpo.gov/otcgi/cfr/otfilter. March 26, 2001.
*EPA. 2001m. Pesticide programs. Exemptions from the requirement of a tolerance. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.1001. http://ecfrback.access.gpo.gov/otcg...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001n. Pesticide programs. Fluorine compounds; tolerances for residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.145. http://ecfrback.access.gpo.gov/otcg...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001o. Superfund. Designation of hazardous substance. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4, Appendix A. http://ecfrback.access.gpo.gov/otcgi/cfr/otfil. March 26, 2001.
*EPA. 2001p. Superfund. The list of extremely hazardous and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://ecfrback.access.gpo.gov/otcgi/cfr/otfil. March 26, 2001.
*EPA. 2001q. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://ecfrback.access.gpo.gov/otcgi...=BSECCT&SUBSET=SUBSET&FROM=1&ITEM=1. March 26, 2001.
*EPA. 2001r. Water pollution. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://ecfrback.access.gpo.gov/otcgi/cf.
*Erickson JD. 1978. Mortality in selected cities with fluoridated and non-fluoridated water supplies. N Eng J Med 298:1112–1116.
Erickson JD. 1980. Down syndrome, water fluoridation, and maternal age. Teratology 21:177–180.6446780
*Erickson JD, Oakley GP Jr, Flynt JW Jr, 1976. Water fluoridation and congenital malformations: No association. J Am Dent Assoc 93:981–984.135009
*Ericsson SY. 1977. Cariostasis mechanisms of fluorides: clinical observations. Caries Res 11(suppl 1):2–23.11044
*Ericsson Y. 1958. The state of fluorine in milk and its absorption and retention when administered in milk. Acta Odontol Scand 16:51–77.
*Ericsson Y, Forsman B. 1969. Fluoride retained from mouth rinses and dentifrices in preschool children. Caries Res 3:290–299.5267928
Ericsson Y, Wei SH. 1979. Fluoride supply and effects in infants and young children. Pediatr Dent 1:44–54.399676
Ericsson Y, Hellstrom I, Hofvander Y. 1972. Pilot studies on the fluoride metabolism in infants on different feedings. Acta Paediatr Scand 61:459–464.5068006
Eriksen N. 1945. A study of the lethal effect of the inhalation of gaseous fluorine (F_2_) at concentrations from 100 ppm to 10,000 ppm. United States Atomic Energy Commission, Pharmacology report 435. University of Rochester, Rochester, New York. NTIS DE85–010190.
*Ernst P, Thomas D, Becklake MR. 1986. Respiratory survey of North American Indian children living in proximity to an aluminum smelter. Am Rev Respir Dis 133:307–312.3946926
*Essman EJ, Essman WB, Valderrama E. 1981. Histaminergic mediation of the response of rat skin to topical fluorides. Arch Dermatol Res 271:325–340.6171209
Evans FG, Wood JL. 1976. Mechanical properties and density of bone in a case of severe endemic fluorosis. Acta Orthop Scand 47:489–495.998183
*Eyde B. 1982. Determination of fluoride in plant material with an ion-selective electrode. Fresenius Z Anal Chem 311:19–22.
Farley JR, Wergedal JE, Baylink DJ. 1983. Fluoride directly stimulates proliferation and alkaline phosphatase activity of bone-forming cells. Science 222:330–332.6623079
*Farley SM, Libanati CR, Mariano-Menez MR, 1990. Fluoride therapy for osteoporosis promotes a progressive increase in spinal bone density. J Bone Miner Res 5(Suppl. 1):37.
Farrah GH. 1964. Diffusion method for determination of urinary fluoride: Recent developments. Am Ind Hyg Assoc J 25:55–58.14110678
FDA. 1977. U.S. Food and Drug Administration. Human Health Services. Code of Federal Regulations. 21 CFR 103.
*FDA. 2000a. Anticaries drug products for over-the-counter human use. Anticaries active ingredients. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 355.10. http://frwebgate.access.gpo.gov/cgi...ON=10&YEAR=2000&TYPE=TEXT. March 27, 2001.
*FDA. 2000b. Anticaries drug products for over-the-counter human use. Labeling of anticaries drug products. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 355.50. http://frwebgate.access.gpo.gov/cgi...ON=50&YEAR=2000&TYPE=TEXT. March 27, 2001.
*FDA. 2000c. Anticaries drug products for over-the-counter human use. Professional labeling. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 355.60. http://frwebgate.access.gpo.gov/cgi...ON=60&YEAR=2000&TYPE=TEXT. March 27, 2001.
*FDA. 2000d. Anticaries drug products for over-the-counter human use. Testing procedures for fluoride dentifrice drug products. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 355.70. http://frwebgate.access.gpo.gov/cgi...ON=70&YEAR=2000&TYPE=TEXT. March 27, 2001.
*FDA. 2000e. Indirect food additives: Adhesives and components of coatings. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105 (c)(5). http://frwebgate.access.gpo.gov/cgi...175&SECTION=105&YEAR=2000&TYPE=TEXT. March 27, 2001.
*FDA. 2000f. Requirements for specific new drugs or devices. Drug products containing certain active ingredients offered over-the-counter. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 310.545 (a)(2). http://frwebgate.access.gpo.gov/cgi...N=545&YEAR=2000&TYPE=TEXT. March 27, 2001.
*FDA. 2000g. Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://frwebgate.access.gpo.gov/cgi...165&SECTION=110&YEAR=2000&TYPE=TEXT. March 27, 2001.
*FDA. 2000h. Substances for use only as components of articles intended for repeated use. Textiles and textile fibers. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 177.2800 (d)(5). http://frwebgate.access.gpo.gov/cgi...77&SECTION=2800&YEAR&TYPE=TEXT. March 27, 2001.
*Featherstone JD B. 1999. Prevention and reversal of dental caries: role of low level fluoride. Comm Dent Oral Epidemiol 27:31–40.
*FEDRIP. 2002. Federal Research in Progress. Dialog Information Services, Inc. Palo Alto, CA.
*Feldman I, Morken D, Hodge HC. 1957. The state of fluoride in drinking water. J Dental Res 36:192–202.
*Fejerskov O, Larsen MJ, Richards, 1994. Dental tissue effects of fluoride. Adv Dent Res (8)1:15–31.7993557
*Fejerskov O, Manji P, Vaelum V. 1990. The nature and mechanisms of dental fluorosis in man. J Dent Res 69(Spec Iss):692–700.2179331
Ferguson DB. 1971. Effects of low dose of fluorides on serum proteins and a serum enzyme in man. Nature (New Biology) 231:159–160.5283022
Feskanich D, Owusu W, Hunter DJ, 1998. Use of toenail fluoride levels as an indicator for the risk of hip and forearm fractures in women. Epidemiology 9:412–416.9647905
Finelli VN, Que Hee S, Niemeier R. 1981. Influence of the aluminum on the toxicology of rats exposed by inhalation to aluminum chloride and fluoride. Gen Pharmacol 12:A13.
*Fisher JR, Sievers ML, Takeshita RT, 1981. Skeletal fluorosis from eating soil. Ariz Med 38:833–835.7316820
*Fisher RL, Medcalf TW, Henderson MC. 1989. Endemic fluorosis with spinal cord compression: A case report and review. Arch Intern Med 149(3):697–700.2919942
*Flaten TP. 1991. A nation-wide survey of the chemical composition of drinking water in Norway. Sci Total Environ 102:35–73.2038665
Fleisch JH, Haisch KD. 1980. Increase in antigen-induced release of slow reacting substance of anaphylaxis from guinea pig lung by sodium fluoride. Biochem Pharmacol 29:1843–1847.6773527
*Fleischer M. 1962. Fluoride content of ground water in the conterminous United States. U.S. Geological Survey Miscellaneous Geological Investigation I-387. Washington, DC: U.S. Geological Survey.
*Fleischer M, Forbes RM, Harriss RC, 1974. Fluorine. In: Geochemistry and the environment. Volume I: The relation of selected trace elements to health and disease. Washington, DC: National Academy of Sciences, 22–25.
Fleming HS, Greenfield VS. 1954. Changes in the teeth and jaws of neonatal Webster mice after administration of sodium fluoride and calcium fluoride to the female parent during gestation. J Dent Res 33:780–788.13211871
Flores EM M, Martins AF. 1997. Distribution of trace elements in egg samples collected near coal power plants. J Environ Qual 26:744–748.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Ekstrand J. 1999. Fluoride intake by infants. J Public Health Dent 59(4):229–234.10682328
*Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forsman B. 1977. Early supply of fluoride and enamel fluorosis. Scand J Dent Res 85:22–30.265081
Franke J. 1979. A new concept of the effect of fluorides on bone. Fluoride 12:195–208.
Franke J. 1989. Difference in skeletal response to fluoride in humans and animals: An overview. Fluoride 22:10–19.
*Franke J, Rath H, Runge F, 1975. Industrial fluorosis. Fluoride 8:61–85.
*Franke J, Runge H, Grau P, 1976. Physical properties of fluorosis bone. Acta Orthop Scand 47:20–27.1266588
Frascino JA, Freed BR, Woodard HQ. 1975. Fluorine-18 metabolism in the acutely uremic rat. Health Phys 29:279–283.1193839
Fratzl P, Roschger P, Eschberger J, 1994. Abnormal bone mineralization after fluoride treatment in osteoporosis: A small-angle X-ray scattering study. J Bone Miner Res 9:1541–1549.7817799
*Freni SC. 1994. Exposure to high fluoride concentrations in drinking water is associated with decreased birth rates. J Toxicol Environ Health 42:109–121.8169995
*Freni SC, Gaylor DW. 1992. International trends in the incidence of bone cancer are not related to drinking water fluoridation. Cancer 70(3):611–618.1623476
*Friend JP. 1989. Natural chlorine and fluorine in the atmosphere, water and precipitation. United Nations Environmental Programme/World Meteorological Association. Scientific Assessment of Stratospheric Ozone: 1989. Alternative Fluorocarbon Environmental Acceptability Study Report.
FSTRAC. 1989. Summary of state and federal drinking water standards and guidelines. Washington, DC: Chemical Communication Subcommittee Federal-State Toxicology and Regulatory Alliance Committee. March 1988.
*Fucsko J, Toth K, Pungor E, 1987. Application of ion-selective electrodes in environmental analysis: Determination of acid and fluoride concentrations in rainwater with a flow-injection system. Anal Chim Acta 194:163–170.
*Fung KF, Zhang ZQ, Wong JW C, 1999. Fluoride contents in tea and soil from tea plantations and the release of fluoride into tea liquor during infusion. Environ Pollut 104:197–205.
Gabler WL, Leong PA. 1979. Fluoride inhibition of polymorphonuclear leukocytes. J Dent Res 58:1933–1939.226570
Gabovich RD, Ovrutskiy CD. 1969. Fluorine in stomatology and hygiene. Bethesda, MD: U.S. Department of Health and Welfare. DHEW publication no. (NIH) 78–785, 1977.
*Gaciri SJ, Davies TC. 1993. The occurrence and geochemistry of fluoride in some natural waters of Kenya. J Hydrol 143:395–412.
Gadhia PK, Joseph S. 1997. Sodium fluoride induced chromosome aberrations and sister chromatid exchange in cultured human lymphocytes. Fluoride 30(3):153–156.
Galletti P-M, Joyet G. 1958. Effect of fluorine on thyroidal iodine metabolism in hyperthyroidism. J Clin Endocr Metab 18:1102–1110.13587625
Galloway HL, Shoaf RE, Skaggs CH, 1975. A rapid method for the determination of fluoride in vegetation: Determination of fluoride in plant samples by a potentiometric method and near-IR reflectance spectroscopy. Am Ind Hyg Assoc J 16:721–724.
Ganesan K, Pandit VI, Dixit SN, 1978. Fluoride industry: Air pollution and its impact on the surrounding area. Indian Environ Health 20:62–69.
Garcia-Ciudad A, Garcia-Criado B, Emeterio CP-S. 1985. Determination of fluoride in plant samples by a potentiometric method and near-IR reflectance spectroscopy. Comm Soil Sci Plant Anal 16:1107–1122.
Garland J. 1963. Sodium fluoride in bone disease. N Engl J Med 269:216–217.
Gaster D, Havivi E, Guggenheim K. 1967. Interrelations of calcium, fluoride, and vitamin D in bone metabolism. Br J Nutr 21:413–418.4952271
*Gdalia I. 1958. Urinary fluorine levels of children and adults. J Dent Res 37:601–604.13563719
Gedalia I. 1970. Distribution in placental and factors. In: Fluorides and human health. Geneva, Switzerland: World Health Organization Monographs Series 59, 12–134.
Gedalia I, Brzezinski A, Bercovici B, 1961. Placental transfer of fluorine in the human fetus. Proc Soc Exper Biol Med 106:147–149.13704133
Gedalia I, Mayer I, Giron J, 1982. Fluoride deposition in the bones of rats determined by fluoride and x-ray diffraction analysis. Archives of Oral Biology 27:823–825.6961895
*Geddes DA M, Bowen WH. 1990. Summary of session III: Fluoride in saliva and dental plaque. J Dent Res 69:637.
Geeraerts F, Gijs G, Finne E, 1986. Kinetics of fluoride penetration into liver and brain. Fluoride 19:108–112.
*Gelberg KH, Fitzgerald EF, Hwang S-A, 1995. Fluoride exposure and childhood osteosarcoma: A case-control study. Am J Pub Health 85(12):1678–1680.7503344
Gerber FJ, Hinn G, Allen D, 1972. Fluorine-18 bone scanning for metastasis detection of bone. NW Med 71:380–384.
*Gerdes RA, Smith JD, Applegate HG. 1971a. The effects of atmospheric hydrogen fluorine upon Drosophila melanogaster: 1. Differential genotypic response. Atmos Environ 5:113–116.5089903
Gerdes RA, Smith JD, Applegate HG. 1971b. The effects of atmospheric hydrogen fluoride upon Drosophila melanogaster: 2. Fecundity, hatchability and fertility. Atmos Environ 5:117–122.5089904
Giavaresi G, Fini M, Gnudi S, 1999. The mechanical properties of fluoride-treated bone in the ovariectomized rat. Calcif Tissue Int 65:237–241.10441658
*Gibbs GW, Horowitz I. 1979. Lung cancer mortality in aluminum reduction plant workers. J Occup Med 21(5):347–353.469596
Gilbert DL. 1985. Environmental effects of airborne fluorides from aluminum smelting at Invergordon, Scotland (UK) 1971–1983. Environ Pollution (Series A) 39:293–302.
*Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Glass RL, Peterson JK, Zuckerberg DA, 1975. Fluoride ingestion resulting from the use of a monofluorophosphate dentrifice by children. Br Dent J 138:423–426.1055597
Glattre E, Wiese H. 1979. Inverse relationship between fluoride and cancer in mouth and throat? Acta Odontol Scand 37:9–14.284707
Glenn FB. 1977. Immunity conveyed by a fluorine supplement during pregnancy. Journal of Dentistry for Children 44:391–395.332731
Glenn FB, Glenn WD, Burdi AR. 1997. Prenatal fluoride for growth and development: Part X. J Dent Child 64(5):317–321.
Glenn FB, Glenn WD, Duncan RC. 1982. Fluoride tablet supplementation during pregnancy for caries immunity: A study of offspring produced. Am J Obstet Gynecol 143(5):560–564.7091227
*Goggin JE, Haddon W, Hambly GS, 1965. Incidence of femoral fractures in postmenopausal women. Public Health Rep 80:1005–1012.4954026
*Goldfrank LR, Flomenbaum NE, Lewin NA, , eds. 1990. Goldfrank's toxicologic emergencies. Norwalk, CT: Appleton & Lange, 198, 220–221, 745, 769–779.
*Goldman SM, Sievers ML, Templin DW. 1971. Radiculomyopathy in a Southwestern Indian due to skeletal fluorosis. Az Med 28:675–677.
*Goldschmidt VM. 1954. Fluorine. In: Muir A, ed. Geochemistry. Oxford, England: Clarendon Press, 568–586.
Golightly LK. 1978. Review of the use of sodium fluoride in the treatment of osteoporosis. Can J Hosp Pharm 31:85–87.
Gopalakrishnan LV. 1980. Studies on the effects of sodium fluoride on cardiac musculature. Cheiron 9:245–249.
Gorban GP, Pliss MB, Karpilovskaya ED, 1975. [The effect of long-term administration of fluorine with food on carcinogenesis and biochemical changes in the liver of rats]. Vopr Pitan 6:21–24. (Russian)
Gordon SL, Corbin SB. 1992. Summary of workshop on drinking water fluoride influence on hip fracture on bone health. Osteoporos Int 2:109–117.1627897
Gorenc B, Babic J. 1975. Potentiometric determination of fluoride in mineral waters by means of an ion-selective electrode. Acta Pharmaceutica Jugoslavica 25:171–176.
Gosselin RE, Smith RP, Hodge HC. 1984. Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams & Wilkens, 112, 185–193.
*Grandjean P, Thomsen G. 1983. Reversibility of skeletal fluorosis. Br J Ind Med 40(4):456–461.6626475
*Grandjean P, Juel K, Jensen OM. 1985. Mortality and cancer morbidity after heavy occupational fluoride exposure. Am J Epidemiol 121:57–64.3964992
*Grandjean P, Olsen JH, Jensen OM, 1992. Cancer incidence and mortality in workers exposed to fluoride. J Natl Cancer Inst 84(24):1903–1909.1460672
Graves CN, Feagin FF. 1988. A method of semi-quantitative microradiographic analysis of root surface lesion remineralization. J Oral Pathol 17:241–249.3144587
Grayson M, ed. 1980. Kirk-Othmer encyclopedia of chemical technology. Vol. 10, 3rd ed. New York, NY: John Wiley & Sons, 630–826.
Greco RJ, Hartford CE, Haith LR Jr, 1988. Hydrofluoric acid-induced hypocalcemia. J Trauma 28:1593–1596.3184225
*Greenberg SR. 1982a. The effect of chronic fluoride exposure on the liver: Part I. The parenchyma. Proc Inst Med Chic 39:53–54.
Greenberg SR. 1982b. Leukocyte response in young mice chronically exposed to fluoride. Fluoride 15:119–123.
*Greenberg SR. 1986. Response of the renal supporting tissues to chronic fluoride exposure as revealed by a special technique. Urol Int 41:91–94.3727197
Greendyke RM, Hodge HC. 1976. Accidental death due to hydrofluoric acid. J Forensic Sci 9(3):383–390.
Gregory AR. 1990. Uncertainty in health risk assessments. Reg Toxicol Pharmacol 11:191–200.
Gregory GL, Harriss RC, Talbot RW, 1986. Air chemistry over the tropical forest of Guyana. J Geophys Res 91(D8):8603–8612.
*Greim H. 1990. Toxicological evaluation of emissions from modern municipal waste incinerators. Chemosphere 20(3/4):317–331.
Grekhova TD, Katsnelson BA, Kolmogortseva VM, 1993. Study on the protective effect of glutamic acid at chronic intoxication with fluoride. Curr Toxicol 1(2):149–159.
Griffith FD, Barnes JR. 1970. Determination of fluoride in urine by fluoride electrode. In: Sunderman FW, ed. Laboratory diagnosis of diseases caused by toxic agents, 215–217.
Griffith GW. 1985. Fluoridation and cancer mortality in Anglesey (Wales, UK). J Epidemiol Community Health 39:224–226.4045363
Grimbergen GW. 1974. A double blind test for determination of intolerance to fluoridated water. Fluoride 7:146–152.
Groeneveld A, Van Eck AAMJ, Backer Dirks O. 1990. Fluoride in caries prevention: is the effect pre- or post-eruptive? J Dent Res 69(special issue):751–5.2179337
Groth EI. 1975. An evaluation of the potential for ecological damage by chronic low-level environmental pollution by fluoride. Fluoride 8:224–240.
*Gruber HE, Baylink DJ. 1991. The effects of fluoride on bone. Clin Orthop Rel Res 267:264–277.
Grucka-Mamczar E, Machoy M, Tarnawski R, 1997. Influence of long-term sodium fluoride administration on selected parameters of rat blood serum and liver function. Fluoride 30(3):157–164.
Gruninger SE, Clayton R, Chang S-B, 1988. Acute oral toxicity of dentifrice fluorides in rats and mice. J Dent Res 67:334.
*Grynpas M. 1990. Fluoride effects on bone crystals. J Bone Miner Res 5:S169–S175.2187325
Grynpas MD, Cheng P-T. 1988. Fluoride reduces the rate of dissolution of bone. Bone and Mineral 5:1–9.3214678
Grynpas MD, Rey C. 1992. The effect of fluoride treatment on bone mineral crystals in the rat. Bone 13:423–429.1476820
Grynpas MD, Hancock RG V, Greenwood C, 1993. The effects of diet, age, and sex on the mineral content of primate bones. Calcif Tissue Int 52:399–405.8504378
Guan Z-Z, Wang Y-N, Xiao K-Q, 1998. Influence of chronic fluorosis on membrane lipids in rat brain. Neurotoxicol Teratol 20(5):537–542.9761592
Guan Z-Z, Zhuang Z-J, Yang P-S, 1988. Synergistic action of iodine-deficiency and fluorine-intoxication on rat thyroid. Chin Med J 101:679–684.3148411
Guenter W, Hahn PH B. 1986. Fluorine toxicity and laying hen performance. Poult Sci 65:769–778.3737509
*Guggenheim K, Simkin A, Wolinsky I. 1976. The effect of fluoride on bone of rats fed diets deficient in calcium or phosphorus. Calcif Tissue Res 22:9–17.1000346
*Guminska M, Sterkowicz J. 1975. Biochemical changes in the blood of humans chronically exposed to fluorides. Acta Med Pol 16:215–224.126634
Guna Sherlin DM, Verma RJ. 2001. Vitamin D ameliorates fluoride-induced embryotoxicity in pregnant rats. Neurotox Teratol 23:197–201.
Guo MK, Nopakun J, Messer HH, 1988. Retention of skeletal fluoride during bone turnover in rats. J Nutr 118:362–366.3351633
*Guo Z, Moisley RB, Wasson SJ, 2001. Dissociation of sulfur hexafluoride tracer gas in the presence of an indoor combustion source. J Air Waste Manage Assoc 51:616–622.
*Gupta SK, Khan TI, Gupta RC. 2001. Compensatory hyperparathyroidism following high fluorine ingestions- a clinico-biochemical correlation. Indian Pediatr 38:139–146.11224578
*Gupta S, Seth AK, Gupta A, 1993. Transplacental passage of fluorides. J Pediatr 123:139–141.8320609
*Gupta SK, Gupta RC, Seth AK, 1995. Increased incidence of spina bifida occulta in fluorosis prone areas. Acta Paediatr Jpn Overseas Ed 37(4):503–506.
Gupta SK, Gupta RC, Seth AK, 1996. Reversal of fluorosis in children. Acta Paediatr Jpn Overseas Ed 38(5):513–519.
*Guy WS, Taves DR, Brey WS Jr. 1976. Organic fluorocompounds in human plasma: Prevalence and characterization. Am Chem Soc Symp Ser 28:117–134.
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. Second edition. Philadelphia, PA: W.B. Saunders Company, 93, 495–496, 1049–1055, 1065–1069,1201, 1210–1211, 1213–1215, 1265, 1481.
Hadjimarkos DM. 1969. Selenium toxicity: Effects of fluoride. Experientia 25:485–486.5796155
*Hagan TL, Pasternack M, Scholz GC. 1954. Waterborne fluorides and mortality. Public Health Rep 69:450–454.13167266
*Haguenauer D, Welch V, Shea B, 2000. Fluoride for the treatment of postmenopausal osteoporotic fractures: a meta-analysis. Osteoporos Int 11:727–38.11148800
Haimanot RT, Fekadu A, Bushra B. 1987. Endemic fluorosis in the Ethiopian Rift Valley. Trop Geogr Med 39:209–217.3433336
*Hall LL, Kilpper RW, Smith FA, 1977. Kinetic model of fluoride metabolism in the rabbit. Environ Res 13:282–302.
Hall RJ. 1963. The spectrophotometric determination of sub-microgram amounts of fluorine in biological specimens. Analyst 88:76–83.
Halton DM, Dranitsaris P, Baynes CJ. 1984. Toxicity levels to humans during acute exposure to hydrogen fluoride. Atomic Energy Control Board, Ottawa, Canada. Report No. CA8508058.
*Hamilton IR. 1990. Biochemical effects of fluoride on oral bacteria. J Dent Res 69(special issue):660–667.2179327
*Han YZ, Zhang JQ, Liu XY, 1995. High fluoride content of food and endemic fluorosis. Fluoride 28(4):201–202.
*Hance CD, Solomon PA, Salmon LG, 1997. Hydrofluoric acid in the southern California atmosphere. Environ Sci Technol 31:956–959.
Hanhijarvi H. 1974. Comparison of free ionized fluoride concentrations of plasma and renal clearance in patients of artificially fluoridated and non-fluoridated drinking water areas. Proc Finn Dent Soc (Supplement III) 70:12.
Hanhijarvi H. 1982. The effect of renal impairment of fluoride retention of patients hospitalized in a low-fluoride community. Proc Finn Dent Soc 78:13–19.7100163
*Hannah RE. 1986. An HPLC anion exclusion method for fluoride determinations in complex effluents. J Chromatogr Sci 24:336–339.
Harris H, Whittaker M. 1963. Differential inhibition of 'usual' and 'atypical' serum cholinesterase by NaCl and NaF. Ann Hum Genet 27:53–58.14059287
*Harris JC, Rumack BH, Bregman DJ. 1981. Comparative efficacy of injectable calcium and magnesium salts in the therapy of hydrofluoric acid burns. Clin Toxicol 18(9):1027–1032.7318388
*Harrison JE, Hitchman AJ W, Hasany SA, 1984. The effect of diet calcium on fluoride toxicity in growing rats. Can J Physiol Pharmacol 62:259–265.6722652
Harrison MF. 1949. Urinary excretion of fluorine in some New Zealand subjects. Br J Nutr 3:166–170.15404529
Harrold GC, Hurlburt RV. 1949. Device and technique for rapid determination of effluent fluorides. Anal Chem 21:1504–1506.
Harwood JE. 1969. The use of an ion-selective electrode for routine fluoride analyses on water samples. Water Res 3:273–280.
*Haskell Laboratory. 1988. Test results of acute inhalation studies with anhydrous hydrogen fluoride with cover letter dated 03/16/88. Newark, DE. EPA/OTS. FYI-OTS-0388–0607.
*Hatai JK, Weber JN, Doizaki K. 1986. Hydrofluoric-acid burns of the eye report of possible delayed toxicity. Journal of Toxicology-Cutaneous and Ocular Toxicology 5:179–184.
Hawley GG. 1977. The condensed chemical dictionary. 9th ed. New York, NY: Van Nostrand Reinhold Co., 390–392.
Hayes WJ Jr. 1975. Ingestion of sodium fluoride as roach powder caused 47 deaths in 260 cases in U.S.A. In: Toxicology of pesticides. Baltimore, MD: Williams & Wilkins, 323.
Haynes RC. 1990. Thyroid and antithyroid drugs. In: Gilman AG, Rall TW, Nies AS, , eds. Goodman and Gilman's: The pharmacological basis of therapeutics. 8th ed. New York, NY: Pergamon Press, 1361–1522.
*HazDat. 2003. Agency for Toxic Substances and Disease Registry (ATSDR). Atlanta, GA. March 2003.
*Heasman MA, Martin AE. 1962. Mortality in areas containing natural fluoride in their water supplies. Mon Bull Minist Health Public Health Lab Serv 21:150–173.13905776
Hedlund LR, Gallagher JC. 1989. Increased incidence of hip fracture in osteoporotic women treated with sodium fluoride. J Bone Miner Res 4:223–225.2728925
Hegsted DH. 1968. The beneficial and detrimental effects of fluorides in the environment. Trace Subst Environ Health 1:105–113.
Heifetz SB, Horowitz HS. 1984. The amounts of fluoride in current fluoride therapies: Safety considerations for children. J Dent Children 4:257–269.
Heifetz SB, Horowitz HS. 1986. Amounts of fluoride in self-administered dental products: Safety considerations for children. Pediatrics 77:876–882.3714382
*Heifetz SB, Driscoll WS, Horowitz HS, 1988. Prevalence of dental caries and dental fluorosis in areas with optimal and above-optimal water-fluoride concentrations: A five-year follow-up survey. J Am Dent Assoc 116:490–495.3259956
*Heilman JR, Kiritsy MC, Levy SM. 1999. Assessing fluoride levels of carbonated soft drinks. JADA 130:1593–1599.10573939
Hein JW, Bonner JF, Brudevold F, 1956. Distribution in the soft tissue of the rat of radioactive fluoride administered as sodium fluoride. Nature 178:1295–1296.13387699
*Heindel JJ, Bates HK, Price CJ, 1996. Developmental toxicity evaluation of sodium fluoride administered to rats and rabbits in drinking water. Fundam Appl Toxicol 30:162–177.8812262
Hellawell JM. 1988. Toxic substances in rivers and streams. Environ Pollut 50:61–85.15092653
*Hemens J, Warwick RJ. 1972. Effects of fluoride on estuarine organisms. Water Res 6:1301–1308.
Henry JA, Hla KK. 1992. Intravenous regional calcium gluconate perfusion for hydrofluoric acid burns. Clin Toxicol 30(2):203–207.
*Henschler D, Buttner W, Patz J. 1975. Absorption, distribution in body fluid and bioavailability of fluoride. In: Kuhlencordt F, Kruse HP, eds. Calcium metabolism, bone and metabolic diseases. Berlin: Springer Verlag, 111–121.
Hering F, Briellmann T, Seiler J, 1985. Fluoridation of drinking water: Effects on kidney stone formation. Urol Res 13:175–178.4049603
*Hernandez-Diaz S, Werler MM, Walker AM, 2001. Neural tube defects in relation to use of folic acid antagonists during pregnancy. Am J Epidemiol 153:961–968.11384952
Hershkowitz I, Norton I. 1963. Increased incidence of melanotic tumors in two strains of Drosophila melanogaster following treatment with sodium fluoride. Genetics 48:307–310.17248154
Heyroth FF. 1963. Halogens. In: Patty F, ed. Industrial hygiene and toxicology. Volume II: Toxicology. 2nd ed. New York, NY: Interscience Publishers, 831–844.
Hibbs CM, Thilsted JP. 1983. Toxicosis in cattle from contaminated well water. Vet Hum Toxicol 25:253–254.6623890
Hilado CJ, Cumming HJ. 1978. Short-term LC50 values: An update on available information. Fire Technol 14:46–50.
Hilado CJ, Furst A. 1976. Short-term LC50 values and fire toxicity. Proc West Pharmacol Soc 19:405–407.996016
Hileman B. 1989. New studies cast doubt on fluoridation benefits. Chem Eng News 67:5–6.
*Hill IN, Blayney JR, Wolf W. 1951. The Evanston dental caries study. VII. The effect of artificially fluoridated water on dental caries experience of 12-, 13-, and 14-year old schoolchildren. J Dent Res 30:670–675.14888768
Hiller S, Cooper C, Kellingray S, 2000. Fluoride in drinking water and risk of hip fracture in the UK: a case-control study. Lancet 355:265–269.10675073
*Hillman D, Bolenbaugh DL, Convey EM. 1979. Hypothyroidism and anemia related to fluoride in dairy cattle. J Dairy Sci 62:416–423.447892
Hindawi IJ. 1968. Injury by sulfur dioxide hydrogen fluoride, and chlorine as observed and reflected on vegetation in the field. J Air Pollut Control Assoc 18:307–312.
Hirano S, Ando M, Kanno S. 1999. Inflammatory responses of rat alveolar macrophages following exposure to fluoride. Arch Toxicol 73(6):310–315.10447558
*Hodge HC. 1950. The concentration of fluorides in drinking water to give the point of minimum caries with maximum safety. J Am Dent Assoc 40:436–439.
Hodge HC. 1960. Notes on the effects of fluoride deposition on body tissues. AMA Arch Ind Health 21:58–60, 350–352.
Hodge HC. 1961. Metabolism of fluorides. JAMA 177:313–316.13714828
Hodge HC, Smith FA. 1970. Air quality criteria for the effects of fluorides on man. J Air Pollut Control Assoc 20:226–232.5439967
Hodge HC, Smith FA. 1972. Chapter 7: Fluorides. In: Lee DH, Minard D, eds. Metallic contaminants and human health. New York, NY: Academic Press, 163–187.
*Hodge HC, Smith FA. 1965. Biological properties of inorganic fluorides. In: Simmons JH, ed. Fluorine chemistry. Vol 4, 2–16.
Hodge HC, Smith FA. 1970. Minerals: Fluorine and dental caries. In: Dietary chemicals vs dental caries. Washington, DC: American Chemical Society, 93–115.
*Hodge HC, Smith FA. 1977. Occupational fluoride exposure. J Occup Med 19:12–39.833695
Hodge HC, Taves DR. 1980. Chronic toxic effects on the kidneys. In: Fluorides and human health. Geneva, Switzerland: World Health Organization, Series 59, 249–255.
*Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoffman DJ, Pattee OH, Wiemeyer SN. 1985. Effects of fluoride on screech owl reproduction: Teratological evaluation, growth, and blood chemistry in hatchlings. Toxicol Lett 26:19–24.4024153
*Hoffman R, Mann J, Calderone J, 1980. Acute fluoride poisoning in a New Mexico elementary school. Pediatrics 65:897–900.7367136
Hogstedt C. 1984. Fluorides. In: Aitio A, Riihimaki V, Vainio H, eds. Biological monitoring and surveillance of workers exposed to chemicals. Washington, DC: Hemisphere Publishing Corporation, 177–186.
Hohenegger M, Huber I, Echsel H, 1986. Metabolites of free fatty acids (FA) and triacylglycerol (TG) in acute and subacute fluoride intoxication of the rat. Arch Toxicol 59:285–289.3827597
Holland RI. 1980. Cytotoxicity of fluoride. Acta Odontol Scand 38:69–79.6445672
Holm AK, Andersson R. 1982. Enamel mineralization disturbances in 12-year old children with known early exposure to fluorides. Community Dent Oral Epidemiol 10:335–336.6961984
*Honein MA, Paulozzi LJ, Mathews TJ, 2000. Impact of folic acid fortification of the U.S. food supply on the occurrence of neural tube defects. JAMA 285:2981–2986.
Hongslo CF, Hongslo JK, Ekstrand J, 1983. Cyclic AMP in urine, kidney, and liver following long-term administration of fluoride to rats. Acta Pharmacol Toxicol 52:276–280.
Hongslo CF, Hongslo JK, Holland RI. 1980. Fluoride sensitivity of cells from different organs. Acta Pharmacol Toxicol 46:73–77.
*Hoover RN, Devesa SS, Cantor KP, 1991a. Review of fluoride benefits and risks. Appendix E. Fluoridation of drinking water and subsequent cancer incidence and mortality. Public Health Service. Bethesda, MD: Department of Health and Human Services.
*Hoover RN, Devesa SS, Cantor KP, 1991b. Review of fluoride benefits and risks. Appendix F. Time trends for bone and joint cancers and osteosarcomas in the surveillance, epidemiology and end results (SEER) program. National Cancer Institute. Public Health Service. Bethesda, MD: Department of Health and Human Services.
*Hoover RN, McKay FW, Fraumeni JF Jr. 1976. Fluoridated drinking water and the occurrence of cancer. J Natl Cancer Inst 57(4):757–768.1003528
*Horowitz HS. 1996. The effectiveness of community water fluoridation in the United States. J Public Health Dent 56:253–258.9034970
Horowitz HS. 2000. Decision-making for national programs of community fluoride use. Commun Dent Oral Epidemiol 28:321–329.
*Horowitz HS, Heifetz SB, Driscoll WS, 1984. A new method for assessing the prevalence of dental fluorosis—the tooth surface index of fluorosis. J Am Dent Assoc 109:37–41.6611361
Howard OH, Weber CW. 1962. An improved continuous internal-electrolysis analyzer for gaseous fluorides in industrial environments. Am Ind Hyg Assoc J 23:48–57.14449368
HSDB. 1989. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information System, Bethesda, MD.
*HSDB. 2003. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. http://toxnet.nlm.nih.gov/cgi-bin/sis/search. March 27, 2001.
*Hudak PF. 1999. Fluoride levels in Texas groundwater. J Environ Sci Health Part A 34(8):1659–1676.
Hudson JT, Stookey GK, Muhler JC. 1967. The placental transfer of fluoride in the guinea pig. Arch Oral Biol 12:237–246.5228189
*Hutton WL, Linscott BW, Williams DB. 1951. The Brantford fluorine experiment: interim report after five years of water fluoridation. Can J Public Health 42:81–87.14821880
*IARC. 1982. Inorganic fluorides used in drinking-water and dental preparations. In: IARC Monographs on the evaluation of carcinogenic risk of chemicals to humans. Vol. 27: Some aromatic amines, anthraquinones and nitroso compounds, and inorganic fluorides used in drinking-water and dental preparations. Lyon, France: World Health Organization, International Agency for Research on Cancer, 237–303.
IARC. 1987. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Supplement 6: Genetic and related effects: An updating of selected IARC monographs from volumes 1 to 42. Lyon, France: World Health Organization, International Agency for Research on Cancer, 15–18, 313, 687–696.
*Ikenishi R, Kitagawa T. 1988. Gas chromatographic method for the determination of fluoride ion in biological samples: II. Stability of fluorine-containing drugs and compounds in human plasma. Chem Pharm Bull 36:810–814.
*Ikenishi R, Kitagawa T, Nishiuchi M, 1988. Gas chromatographic method for the determination of fluoride ion in biological samples: I. Fluoride level in monkey. Chem Pharm Bull 36:662–669.
Imai T, Niwa M, Ueda M. 1983. The effects of fluoride on cell growth of two human cell lines and on DNA and protein synthesis in HeLa cells. Acta Pharmacol Toxicol 52:8–11.
Imandel K, Khodabandeh A, Mesghaly A, 1977. Epidemiology of fluorosis in the Borazjan area of Iran: I. Fluoride content in drinking water. Southeast Asian J Trop Med Public Health 8:87–88.888000
*IOM. 1997. Dietary reference intakes for calcium, phosphorus, magnesium, vitamin D, and fluoride. Washington, DC: Institute of Medicine. National Academy of Sciences. National Academy Press. www4.nationalacademies.org/iom/iomhome.nsf.
*IRIS. 2003. Fluorine (soluble fluoride). Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. April 02, 2003.
*Ismail A, Bandekar RR. 1999. Fluoride supplements and fluorosis: A meta-analysis. Commun Dent Oral Epidemiol 27:48–56.
Iyer BV, Fox JL, Higuchi WI, 1983. A new acid abrasion procedure for studying F profiles in demineralized/remineralized bovine tooth enamel. Caries Res 17:297–300.6347384
*Jaccaud M, Faron R. 1988. Fluorine. In: Gerhartz W, Yamamoto YS, Campbell FT, , eds. Ullmann's encyclopedia of industrial chemistry. Weinheim: VCH, Volume 11, 293–306.
Jachimczak D, Skotarczak B. 1978. The effect of fluorine and lead ions on the chromosomes of human leukocytes in vitro. Genetica Polonica 19:353–357.
*Jackson D, Weidmann SM. 1959. The relationship between age and the fluorine content of human dentine and enamel: A regional survey. Br Dent J 107:303–306.
*Jackson JR, Hammersley H. 1981. Biological monitoring for occupational fluoride absorption. Fluoride 14:75–86.
*Jackson RD, Brizendine EJ, Kelly SA, 2002. The fluoride content of foods and beverages from negligibly and optimally fluoridated communities. Community Dent Oral Epidemiol 30:382–391.12236830
*Jackson RD, Kelly SA, Katz BP, 1995. Dental fluorosis and caries prevalence in children residing in communities with different levels of fluoride in the water. J Public Health Dent 55:79–84.7643331
*Jacobsen SJ, Goldberg J, Cooper C, 1992. The association between water fluoridation and hip fracture among white women and men aged 65 years and older. Ann Epidemiol 2:617–626.1342313
*Jacobsen JS, Goldberg J, Miles TP, 1990. Regional variation in the incidence of hip fracture: U.S. white women aged 65 years and older. JAMA 264:500–502.2366282
*Jacobsen JS, O’Fallon M, Melton J. 1993. Hip fracture incidence before and after the fluoridation of the public water supply, Rochester, Minnesota. Am J Pub Health 83(5):743–745.8484462
*Jacobson JS, Heller LI. 1971. Selective ion electrode analysis of fluoride in vegetation. In: England HM, Beery WT, eds. Proceedings of the Second International Clean Air Congress. New York, NY: Academic Press, 459–462.
Jacobson JS, Weinstein LH. 1977. Sampling and analysis of fluoride: Methods for ambient air, plant and animal tissues, water, soil, and foods. J Occup Med 19:79–87.833696
Jacobson JS, Weinstein LH, Farrah GH. 1972. Review of methods for monitoring the fluoride content of air. In: Rampacek C, ed. Environmental Control; Proceedings of Symposium. New York, NY: AIME, 119–134.
Jacyszyn K, Marut A. 1986. Fluoride in blood and urine in humans administered fluoride and exposed to fluoride-polluted air. Fluoride 19:26–32.
Jagiello G, Lin JS. 1974. Sodium fluoride as potential mutagen in mammalian eggs. Arch Environ Health 29:230–235.4472310
*Jain SK, Susheela AK. 1987. Effect of sodium fluoride on antibody formation in rabbits. Environ Res 44:117–125.3653065
*Jansen I, Thomson HM. 1974. Heart deaths and fluoridation. Fluoride 7:52–57.
*Jarnberg P-O, Ekstrand J, Ehrnebo M. 1983. Renal excretion of fluoride during water diuresis and induced urinary pH- changes in man. Toxicol Lett 18:141–146.6623538
Jarnberg P-O, Ekstrand J, Irestedt L, 1979. Renal function and fluoride formation and excretion during enflurane anaesthesia. Acta Anaesthesiol Scand 23:444–452.532540
*Jarnberg P-O, Ekstrand J, Irestedt L, 1980. Renal fluoride excretion during and after enflurane anesthesia: Dependency on spontaneous urinary pH-variations. Acta Anesthesiol Scand 24:120–134.
*Jarnberg P-O, Ekstrand J, Irestedt L, 1981. Renal fluoride excretion and plasma fluoride levels during and after enflurane anesthesia are dependent on urnary pH. Anesthesiology 54:48–52.7457982
*Jeandel C, Flapicuie F, Netter P, 1992. Effect of age on the disposition of sodium fluoride. Eur J Clin Pharmacol 43:295–297.1425895
Jech JA. 1979. Comparative uptake of fluoride from sodium fluoride, ammonium fluoride, and barium fluoride in rat teeth when predominantly administered in the pre-eruptive stage of development. Calcif Tissue Int 27:117–119.110413
Jenkins GN, Edgar WM. 1973. Some observations on fluoride metabolism in Britain. J Dent Res 52:984–985.
Jethanandani P, Sharma K, Susheela AK. 1995. Circulating heptoglobin of rabbits after acute and chronic fluoride activity. Med Sci Res 23(5):301–303.
Jha LB, Jha M. 1982. Fluoride pollution in India. Int J Environ Stud 19:225–230.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson M. 1976. Potentiometric method for the determination of fluoride in vegetation. Fluoride 9:54–63.
Johnson WJ, Taves DR. 1974. Exposure to excessive fluoride during hemodialysis. Kidney Int 5:451–454.4424337
Johnson WJ, Taves DR, Jowsey J. 1979. Fluoridation and bone disease in renal patients. In: Johnson E, Taves DR, Olson T, eds. Continuing evaluation of the use of fluorides. Boulder, CO: Westview Press for the American Association for the Advancement of Science, 275–293.
Jolly SS. 1976. Fluoride balance studies in endemic fluorosis. Fluoride 8:138–147.
*Jones AT. 1939. The treatment of hydrofluoric acid burns. J Ind Hyg Toxicol 21:205–212.
Jones J, Riley M, Couper D, 1999. Water fluoridation, bone mass and fracture: a quantitative overview of the literature. Aust NZ J Public Health 23:34–40.
*Jooste PL, Weight MJ, Kriek JA, 1999. Endemic goiter in the absence of iodine deficiency in schoolchildren of the Northern Cape Province of South Africa. Eur J Clin Nutr 53:8–12.10048794
*Jowsey J, Riggs BL. 1978. Effects of concurrent calcium ingestion on intestinal absorption of fluoride. Metabolism 27(8):971–974.672616
Juncos LI, Donadio JV Jr. 1972. Renal failure and fluorosis. JAMA 222:783–785.4677926
Kabrt L, Sucha L. 1980. Determination of fluorides in the atmosphere: I. Permeation tubes as a standard source of hydrogen fluoride for the preparation of atmospheric model samples. Anal Chem H 15:103–112.
Kahl S, Ewy-Dura A. 1976. Effect of fluoride on the red cell (51Cr label), plasma (125IHSA label) and true blood volumes of rats. Bulletin de ĽAcademie Polonaise des Sciences 24:397–402.
*Kakabadse GJ, Manohn B, Bather JM, 1971. Decomposition and the determination of fluorine in biological materials. Nature 299:626–627.
*Kalsbeek H, Kwant GW, Groeneveld A. 1993. Caries experience of 15-year old children in the Netherlands after discontinuation of water fluoridation. Caries Res 27:201–205.8519058
*Kaltreider NL, Elder MJ, Cralley LV, 1972. Health survey of aluminum workers with special reference to fluoride exposure. J Occup Med 14:531–541.5036207
*Kaminsky L, Mahony M, Leach J, 1990. Fluoride: Benefits and risks of exposure. Crit Rev Oral Biol Med 1:261–281.2129630
Kanisawa M, Schroeder HA. 1969. Life term studies on the effect of trace elements on spontaneous tumors in mice and rats. Cancer Res 29(4):892–895.5777793
Kanwar KC, Singh M. 1981a. Zinc, copper, and manganese levels in various tissues following fluoride administration. Experientia 37:1328–1329.7327247
Kanwar KC, Singh M. 1981b. Zinc depletion following experimental fluorosis in mice. Sci Total Environ 22:79–83.7336202
Kao W-F, Dart RC, Kuffner E, 1999. Ingestion of low-concentration hydrofluoric acid: An insidious and potentially fatal poisoning. Ann Emerg Med 31:35–41.
*Karagas MR, Baron JA, Barrett JA, 1996. Patterns of fracture among the United States elderly: Geographic and fluoride effects. Ann Epidemiol 6:209–216.8827156
Kay E. 1974. An inquiry into the distribution of fluoride in the environmental of Garrison, Montana. Fluoride 7:7–31.
Kay MI, Young RA, Posner AS. 1964. Crystal structure of hydroxyapatite. Nature 204:1050–1052.14243377
Kazimierczak W, Adamas B. 1980. The action of various fluorides on rat mast cells: A comparative study. Arch Immunol Ther Exp 28:941–946.
Kekki M, Lampainen E, Kauranen P, 1982. The nonlinear tissue-binding character of fluoride kinetics in normal and anephric subjects. Graphical analysis of serum fluoride data from man and rabbit. Nephron 31:129–134.7121655
*Kelly TJ, Mukund R, Spicer CW, 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28:378–387.
*Kelly TJ, Ramamurthi M, Pollack AJ, 1993. Ambient concentration summaries for Clean Air Act. Title III. Hazardous air pollutants. Final Report. Research Triangle Park, July 1993.
Kelso FS, Matthews JM, Kramer HP. 1964. Ion-exchange method for determination of fluoride in potable waters. Anal Chem 36:577–579.
*Kemp FH, Murray MM, Wilson DC. 1942. Spondylosis deformans in relation to fluorine and general nutrition. Lancet ii:293–296.
Kempf CA, Greenwood DA, Nelson VE. 1937. Studies relating to the toxicity of fluorine compounds. J Lab Clin Med 22:1133–1137.
*Keplinger ML. 1969. Effects from repeated short-term inhalation of fluorine. Toxicol Appl Pharmacol 14:192–200.5775557
*Keplinger ML, Suissa LW. 1968. Toxicity of fluorine short-term inhalation. Am Ind Hyg Assoc J 29(1):10–18.5667185
Kessabi M, Assimi B, Braun JP. 1984. The effects of fluoride on animals and plants in the south Safi zone. Sci Total Environ 38:63–69.6523125
Kessabi M, Braun JP, Bernard P, 1980. Acute kidney toxicity of sodium fluoride in the rat. Toxicol Lett 5:169–174.6110256
Kessabi M, Braun JP, Burgat-Sacaze V, 1981. Comparison of sodium and stannous fluoride nephrotoxicity. Toxicol Lett 7:463–467.6113698
*Kessabi M, Hamliri A, Braun JP, 1985. Experimental acute sodium fluoride poisoning in sheep: Renal, hepatic, and metabolic effects. Fundam Appl Toxicol 5:1025–1033.2868958
*Khalil AM. 1995. Chromosome aberrations in cultured rat bone marrow cells treated with inorganic fluorides. Mutat Res 343:67–74.7753108
*Khalil AM, Da'dara AA. 1994. The genotoxic and cytotoxic activities of inorganic fluoride in cultured rat bone marrow cells. Arch Environ Contam Toxicol 26:60–63.8110024
*Khandare AL, Kumar PU, Lakshmaiah N. 2000. Beneficial effect of tamarind ingestion on fluoride toxicity in dogs. Fluoride 33(1):33–38.
Khandare AL, Rao GS, Lakshmaiah N. 2002. Effect of tamarind ingestion on fluoride excretion in humans. European J Clin Nutr 56:82–85.11840184
Kick CH, Bethke RM, Edgington BH. 1933. Effect of fluorine on the nutrition of swine with special reference to bone and tooth composition. J Agric Res 46:1023–1037.
*Kidd EA M, Thylstrup A, Fejerskov O, 1980. Influence of fluoride in surface enamel and degree of dental fluorosis on caries development in vitro. Caries Res 14:196–202.6929731
Kierdorf H, Kierdorf U. 1999. Reduction of fluoride deposition in the vicinity of a brown coal-fired power plant as indicated by bone fluoride concentrations of Roe deer. Bull Environ Contam Toxicol 63:473–477.10501724
*Kierdorf H, Kierdorf U. 2000. Roe deer antlers as monitoring units for assessing temporal changes in environmental pollution by fluoride and lead in a German forest area over a 67-year period. Arch Environ Contam Toxicol 39:1–6.10790495
King EJ, Yoganathan M, Nagelschmidt G. 1958. Tissue reactions produced by calcium fluoride in the lungs of rats. Br J Ind Med 15:168–171.13596534
Kinlen L. 1975. Cancer incidence in relation to fluoride level in water supplies. Br Dent J 138:221–224.1054601
*Kinlen L, Doll R. 1981. Fluoridation of water supplies and cancer mortality: III. A re-examination of mortality in cities in the U.S.A. J Epidemiol Community Health 35:239–244.7338697
Kirkpatrick RL. 1980. Regulatory aspects of fluoride toxicity. J Anim Sci 51:773–774.6893708
*Klauder JV, Shelanski L, Gabriel K. 1955. Industrial uses of compounds of fluorine and oxalic acid. AMA Archives of Industrial Health 12:412–419.13257934
Kleerekoper M. 1994. Non-dental tissue effects of fluoride. Adv Dent Res 8(1):32–38.7993558
Kleerekoper M. 1996. Fluoride and the skeleton. In: Bilezikian JP, Raisz LG, Rodan GA, eds. Principles of bone biology. San Diego, CA: Academic Press, 1053–1062.
*Kleerekoper M, Peterson EL, Nelson DA, 1991. A randomized trial of sodium fluoride as a treatment for postmenopausal osteoporosis. Osteoporos Int 1:155–61.1790403
Kleerekoper M, Peterson E, Phillips E, 1989. Continuous sodium fluoride therapy does not reduce vertebral fracture rate in postmenopausal osteoporosis [Abstract]. J Bone Miner Res 4(1):S376.
Kleineberg GA, Geiger DL. 1975. Toxic hazard evaluation by mass spectrometric thermal analysis. In: Proceedings of the 6th Annual Conference on Environmental Toxicology, 21, 22, and 23 October 1975. Aerospace Medical Research Laboratory, 199–216.
Kleiner HS, Allmann DW. 1982. The effects of fluoridated water on rat urine and tissue cAMP levels. Arch Oral Biol 27:107–112.6282241
*Kleinfeld M. 1965. Acute pulmonary edema of chemical origin. Arch Environ Health 10:942–946.14308834
Knaus RM. 1971. The fate of fluoride and the effect of fluoride upon glucose metabolism in intact rats [Abstract]. Diss Abst Int (Section B): Sciences and Engineering 32(4):2010B.
*Knaus RM, Dost FN, Johnson DE, 1976. Fluoride distribution in rats during and after continuous infusion of Na^18^F. Toxicol Appl Pharmacol 38:335–343.996864
*Knight HG, Furr AK, Parkinson TF. 1988. Determination of fluorine by neutron activation analysis. Anal Chem 49:1507–1510.
Knouff RA, Edwards LF, Preston DW, 1936. Permeability of placenta to fluoride. J Dent Res 15:291–294.
Koh ET, Clarke SL. 1997. Effects of fluoride and aluminum exposure to dams prior to and during gestation on mineral compositions of bone and selected soft tissues of female mice dams and pups. FASEB J 11(3):A406.
Kojima T, Ichise M, Seo Y. 1972. Selective gas-chromatography detection using an ion-selective electrode: II. Selective detection of fluorine compounds. Talanta 19:539–547.18961082
*Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Kono K, Watanabe T, Dote T, 2000. Successful treatments of lung injury and skin burn due to hydrofluoric acid exposure. Int Arch Occup Environ Health 73:S93–S97.10968568
Kono K, Yoshida Y, Harada A, 1982. Fluoride metabolism and renal function: Concerning health care of hydrofluoric acid workers. Proceedings of the Tenth Asian Conference On Occupational Health 2:755–762.
*Kono K, Yoshida Y, Watanabe M, 1984. Urinary fluoride excretion in fluoride exposed workers with diminished renal functions. Ind Health 22:33–40.6725016
Kono K, Yoshida Y, Watanabe M, 1992a. An experimental study on the treatment of hydrofluoric acid burns. Arch Environ Contam Toxicol 22:414–418.1586204
Kono K, Yoshida Y, Watanabe M, 1992b. Serum fluoride as an indicator of occupational hydrofluoric acid exposure. Int Arch Occup Environ Health 64:343–346.1487331
*Kono K, Yoshida Y, Watanabe M, 1993. Urine, serum and hair monitoring of hydrofluoric acid workers. Int Arch Occup Environ Health 65:S95–S98.8406947
*Kono K, Yoshida Y, Yamagata H, 1987. Urinary fluoride monitoring of industrial hydrofluoric acid exposure. Environ Res 42:415–520.3569181
Koskinen-Kainulainen M, Luoma H. 1987. Excretion, serum, bone and kidney levels of F in rats after high single dose of F and Mg+F. Magnesium 6:212–219.3669731
*Koulourides T. 1990. Summary of session II: fluoride and the caries process. J Dent Res 69(special issue):558.
Kour K, Singh J. 1980. Histological finding of mice testis following fluoride ingestion. Fluoride 13:160–162.
*Kram D, Schneider EL, Singer L, 1978. Effects of high and low fluoride diets on the frequencies of sister chromatid exchanges. Mutat Res 57:51–55.642967
*Krasowska A, Wlostowski T. 1992. The effect of high fluoride intake on tissue trace elements and histology of testicular tubules in the rat. Comp Biochem Physiol 103C(1):31–34.
*Krelowska-Kulas M. 1994. Content of fluorine in vegetables and fruits from an industrial area. Nahrung 38(4):397–401.7935742
Krishnamachari KA, Krishnaswamy K. 1974. An epidemiological study of the syndrome of Genu valgum among residents of endemic areas for fluorosis in Andhra Pradesh. Indian J Med Res 62:1415–1423.4443000
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ II I, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kröger H, Alhava E, Honkanen R, 1994. The effect of fluoridated drinking water on axial bone mineral density: A population-based study. Bone Mineral 27:33–41.7849544
*Krook L, Maylin GA. 1979. Industrial fluoride pollution: Chronic fluoride poisoning in Cornwall Island cattle. Cornell Vet 69(Supplement 8):3–70.455991
Kruger BJ, Patterson CM, Masters CJ. 1978. Species differences in uptake and distribution of 18F. Aust J Exp Biol Med Sci 56:427–431.728000
Kucharz E, Drozdz M, Jendryczko A. 1986. Influence of fluoride compounds on lysosomal enzymes activity in blood of growing rats. Revue Roumaine de Biochimie 23:115–118.
Kudo A, Garrec JP. 1983. Accidental release of fluoride into experimental pond and accumulation in sediments, plants, algae, molluscs and fish. Regul Toxicol Pharmacol 3:189–198.6635267
*Kuhr J, Helbig J, Anders G, 1987. Interactions between fluorides and magnesium. Magnesium-Bulletin 9:110–113.
*Kumar A, Susheela AK. 1994. Ultrastructural studies of spermiogenesis in rabbit exposed to chronic fluoride toxicity. Int J Fertil 39(3):164–171.
*Kumar A, Susheela AK. 1995. Effects of chronic fluoride toxicity on the morphology of ductus epididymis and the maturation of spermatozoa of rabbit. Int J Exp Pathol 76:1–11.7734335
Kumar JV, Green EL. 1998. Recommendations for fluoride use in children. NY State Dent J Feb:41–48.
Kumar SP, Harper K. 1963. Fluorosis in Aden. Br J Radiol 36(427):497–502.
Kumari DS, Rao PR. 1991. Red cell membrane alterations in human chronic fluoride toxicity. Biochem Int 23(4):639–648.1831358
*Kumpulainen J, Koivistoinen P. 1977. Fluorine in foods. Residue Rev 68:37–55.337435
*Künzel W, Fischer T. 1997. Rise and fall of caries prevalence in German towns with different F concentrations in drinking water. Caries Res 31:166–173.9165185
*Künzel W, Fischer T. 2000. Caries prevalence after cessation of water fluoridation in La Salud, Cuba. Caries Res 34:20–25.10601780
*Künzel W, Fischer T, Lorenz R, 2000. Decline of caries prevalence after the cessation of water fluoridation in the former East Germany. Commun Dent Oral Epidemiol 28:382–389.
Kuo HC, Stamm JW. 1974. Fluoride levels in human rib bone: A preliminary study. Can J Public Health 65:359–361.4447914
*Kurttio R, Gustavsson N, Vartiainen T, 1999. Exposure to natural fluoride in well water and hip fracture: A cohort analysis in Finland. Am J Epidemiol 150:817–824.10522652
Kyle RA, Jowsey J. 1980. Effect of sodium fluoride, calcium carbonate, and vitamin D on the skeleton of multiple myeloma. Cancer 45:1669–1674.6989479
Lantz EM, Smith MC. 1934. The effect of fluorine on calcium and phosphorus metabolism in albino rats. Am J Physiol 109:645–654.
*Lantz O, Jouvin MH, DeVernejoul MC, 1987. Fluoride-induced chronic renal failure. Am J Kidney Dis 10:136–139.3605090
Larez A, Ochoa Y, Aponte N, 1980. Sodium fluoride, fetotoxicity, and oral experimental teratogeny in rats: Toxicol aspects. International Congress of the European Association of Poison Control Centers 9th 1980, 528–540.
Largent EJ. 1952. Rates of elimination of fluoride stored in the tissue of man. AMA Arch Ind Hyg Occup Med 6:37–42.14932526
Largent EJ. 1954. Metabolism of inorganic fluorides. In: Fluoridation as a public health measure. Washington, DC: American Association for the Advancement of Science, 49–78.
*Largent EJ. 1960. The metabolism of fluorides in man. AMA Archives of Industrial Health 21:318–323.14414185
Larner J. 1950. Toxicological and metabolic effects of fluorine-containing compounds. Ind Med Surg 19:535–539.14784375
Larsen S, Widdowson AE. 1971. Soil fluorine. J Soil Sci 22:210–221.
Larsen MJ, Kirkegaard E, Poulsen S. 1987. Patterns of dental fluorosis in a European country in relation to the fluoride concentration of drinking water. J Dent Res 66:10–12.3476536
Lasne C, Lu YP, Chouroulinkov I. 1988. Transforming activities of sodium fluoride in cultured Syrian hamster embryo and BALB/3T3 cells. Cell Biol Toxicol 4:311–324.3224306
Latham MC, Grech P. 1967. The effects of excessive fluoride intake. Am J Public Health 57:651–660.
Laurema S, Varis A-L. 1987. The fluoride content of Finnish honey. J Agric Sci Finland 59:379–386.
Laurence JA. 1982. Monitoring fluoride in the environment. In: Murray F, ed. Fluoride emissions. 1st ed. North Ryde, Australia: Academic Press, 45–51.
*Lawrenz M, Mitchell HH, Ruth RA. 1940. Adaptation of the growing rat to the ingestion of a constant concentration of fluorine in the diet. J Nutr 19:531–546.
Lavoie EJ, Colement DT, Geddie NG, 1985. Studies on the mutagenicity and tumor-initiating activity of methylated fluorenes. Chem Biol Interact 52:301–309.3882256
Lee C, Jacobs WB. 1968. The absorption, distribution, excretion, and toxicity of trifluoroamine oxide. Toxicol Appl Pharmacol 13:76.
Lee JR. 1975. Optimal fluoridation: The concept and its application to municipal water fluoridation. West J Med 122:431–436.1130041
Lee JR. 1983. Gilberťs disease and fluoride intake. Fluoride 16:139–145.
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
LeGeros RZ. 1990. Chemical and crystallographic events in the caries process. J Dent Res 69(special issue):567–574.2179315
*Lehmann R, Wapniarz M, Hofmann B, 1998. Drinking water fluoridation: Bone mineral density and hip fracture incidence. Bone 22:273–278.9514220
Leonard CD, Graves HB Jr. 1973. Effect of fluorine level in Valencia orange leaves on yield and fruit quality. Proc State Florida Horticult Soc 85:13–18.
Leonard MA, Murray GT. 1974. Sulphonated alizarin fluorine blue: An improved reagent for the positive absorptiometric determination of the fluoride ion. Analyst 99:645–651.
Leone NC, Leatherwood EC, Petrie IM, 1964. Effect of fluoride on thyroid gland: Clinical study. J Am Dental Assoc 69:179–180.
Leone NC, Martin AE, Minoguchi G, 1970. Fluorides and general health. Geneva, Switzerland: World Health Organization, Series 59, 273–321.
*Leone NC, Shimkin MB, Arnold FA, 1954. Medical aspects of excessive fluoride in a water supply. Public Health Reports 69(10):925–936.13204526
*Leone NC, Stevenson CA, Hilbish TA, 1955. A roentgenologic study of a human population exposed to a high-fluoride domestic water: A ten year study. Am J Roentgenol Radium Ther Nucl Med 74(5):874–885.
Less LN, McGregor A, Jones LH, 1975. Fluorine uptake by grass from aluminum smelter fume. Int J Environ Stud 7:153–160.
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Leverett DH. 1986. Prevalence of dental fluorosis in fluoridated and nonfluoridated communities - a preliminary investigation. J Public Health Dent 46:184–187.3465957
Levi S, Zilberman L, Frumin A, 1986. Exposure to fluoride in the chemical industry. Am J Ind Med 9:153–158.3008553
*Levine RS. 1976. The action of fluoride in caries prevention: a review of current concepts. Br Dent J 140:9–14.1061590
*Levy SM. 1994. Review of fluoride exposures and ingestion. Community Dent Oral Epidemiol 22:173–180.8070245
Levy SM, Zavash Z-M. 1991. Evaluation of fluoride exposures in children. J Dent Child 58:467–473.
*Levy SM, Kohout FJ, Guha-Chowdhury N, 1995b. Infants’ fluoride intake from drinking water alone, and from water added to formula, beverages, and food. J Dent Res 74:1399–1407.7560391
*Levy SM, Kiritsy MC, Warren JJ. 1995a. Sources of fluoride intake in children. J Public Health Dent 55:39–52.7776292
*Levy SM, Warren JJ, Davis CS, 2001. Patterns of fluoride intake from birth to 36 months. J Public Health Dent 61:70–77.11474917
*Lewis RJ Sr. ed. 1997. Hawley’s Condensed Chemical Dictionary. 13^th^ ed. New York, NY: John Wiley & Sons, Inc., 511, 1017.
Li J, Suzuki Y, Hayashi K, 1991. The genotoxic effect of sodium fluoride [Abstract]. Mutat Res 252(1):95.
*Li XS, Zhi JL, Gao RO. 1995a. Effect of fluoride exposure on intelligence in children. Fluoride 28(4):189–192.
*Li Y, Liang CK, Katz BP, 1995b. Long-term exposure to fluoride in drinking water and sister chromatid exchange frequency in human blood lymphocytes. J Dent Res 74(8):1468–1474.7560401
*Li Y, Liang CK, Slemenda CW, 2001. Effect of long term exposure to fluoride in drinking water on risks of bone fractures. J Bone Miner Res 16(5):932–939.11341339
*Li YM, Dunipace AJ, Stookey GK. 1987a. Effects of fluoride on the mouse sperm morphology test. J Dent Res 66:1509–1511.3476624
Li YM, Dunipace AJ, Stookey GK. 1988. Genotoxic effects of fluoride: A controversial issue. Mutat Res 195:127–136.3123922
*Li YM, Heerema NA, Dunipace AJ, 1987b. Genotoxic effects of fluoride evaluated by sister-chromatid exchange. Mutat Res 192:191–201.3683439
Liberti A, Mascini M. 1969. Anion determination with ion selective electrodes using Gran's plot. Anal Chem 41:676–679.
*Lide DR, ed. 1992. CRC handbook of chemistry and physics. 73th ed. Boca Raton FL: CRC Press, Inc, 4–62, 4–98.
Likins RC, McClure FJ, Steere AC. 1962. Urinary excretion of fluoride following defluoridation of a water supply. In: McClure FJ, ed. Fluoride drinking waters. Bethesda, MD: U.S. Department of Health, Education and Welfare, Public Health Service, National Institute of Dental Research, 421–423.
*Lim JK, Renaldo GJ, Chapman P. 1978. LD50 of stannous fluoride, sodium fluoride and sodium mono-fluoro phosphate in the mouse compared to the rat. Caries Res 12:177–179.272954
Lindahl CB, Mahmood T. 1994. Fluorine compounds, inorganic. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. 4^th^ Edition, Vol. 11. New York, NY: John Wiley and Sons, 426–428.
Lindahl D, Lindwall L. 1978. Physical properties of fluorosis bone: Critical comments. Acta Orthop Scand 49:382–383.696278
Linde HW. 1959. Estimation of small amounts of fluoride in body fluids. Anal Chem 31:2092–2094.
*Litvinov NN, Sikivuev JN. 1973. Tumours of the bone. In: Tursov VS, ed. Pathology of tumours in laboratory animals. Vol 1: Tumours of the rat. Lyon, France: World Health Organization, International Agency for Research on Cancer, 169–184.
Liu M, Sun RY, Zhang JH, 1987. Elimination of excess fluoride in potable water with coacervation by electrolysis using an aluminum anode. Fluoride 20:54–63.
*Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Loftenius A, Andersson B, Butler JE, 1999. Fluoride augments the mitogenic and antigenic response of human blood lymphocytes in vitro. Caries Res 33:148–155.9892783
*Lopez H, Navia JM. 1988. A method to assay fluoride in foods, beverages, and diets. Caries Res 22:210–216.3165712
Lu FC, Grewal RS, Rice WB, 1965. Acute toxicity of sodium fluoride for rhesus monkeys and other laboratory animals. Acta Pharmacol Toxicol 22:99–106.
*Lu Y, Sun ZR, Wu LN, 2000. Effect of high-fluoride water on intelligence in children. Fluoride 33(2):74–78.
Lucas J. 1988. Fluorine in the natural environment. J Fluorine Chem 41:1–8.
Lucas PA, Ophaug RH, Singer L. 1984. The effect of vitamin A deficiency and fluoride on glycosaminoglycan metabolism in bone. Connect Tissue Res 13:17–26.6242393
*Luke J. 2001. Fluoride deposition in the aged human pineal gland. Caries Res 35:125–128.11275672
*Lund K, Ekstrand J, Boe J, 1997. Exposure to hydrogen fluoride: an experimental study in humans of concentrations of fluoride in plasma, symptoms, and lung function. Occup Environ Med 54(1):32–37.9072031
*Lund K, Refsnes M, Ramis I, 2002. Human exposure to hydrogen fluoride induces acute neutrophilic eicosanoid, and antioxidant changes in nasal lavage fluid. Inhal Toxicol 14:119–132.12122575
*Lund K, Refsnes M, Sandstrom T, 1999. Increased CD3 positive cells in bronchoalveolar lavage fluid after hydrogen fluoride inhalation. Scand J Work Environ Health 25(4):326–334.10505658
*Luoma H. 1980. Fluoride and magnesium, two ions in the prevention of calcium salt imbalance, including caries prevention, in man and animals. Proc Finn Dent Soc 76:73–81.7443691
Lynch CF. 1987. Relationship of fluoride in drinking water to other drinking water parameters. Arch Environ Health 42:5–13.3566351
*Lyon JS. 1962. Observations on personnel working with fluorine at a gaseous diffusion plant. J Occup Med 4:199–201.14467626
Ma TS. 1958. Determination of fluorine in quantitative organic microanalysis. Anal Chem 30:1557–1560.
Mabury SA, Ellis DA. 2001. ^19^F NMR as a highly specialized tool for the investigation of fluoro-chemicals of environmental interest. ACS Abstracts 22(1–2):37.
MacDonald DJ, Luker MA. 1980. Fluoride: Interaction with chemical mutagens in drosophila. Mutat Res 71:211–218.6771647
*Macejunas AG. 1969. Spectrophotometric determination of fluoride using zirconium. J Amer Water Works Assoc 61:311–313.
*Machle W, Kitzmiller K. 1935. The effects of the inhalation of hydrogen fluoride: II. The response following exposure to low concentration. J Ind Hyg Toxicol 17:223–229.
*Machle W, Largent EJ. 1943. The absorption and excretion of fluoride: II. The metabolism at high levels of intake. J Ind Hyg Toxicol 25:112–123.
*Machle W, Scott EW. 1935. The effects of the inhalation of hydrogen fluoride: III. Fluorine storage following exposure to sub-lethal concentrations. J Ind Hyg 17:230–240.
Machle W, Scott EW, Largent EJ. 1942. The absorption and excretion of fluoride: I. The normal fluoride balance. J Ind Hyg Toxicol 24:199–202.
Machle W, Scott EW, Treon J. 1969. Normal urinary fluorine excretion and the fluorine content of food and water. Amer J Hyg 29:139–145.
*Machle W, Thamann F, Kitzmiller K, 1934. The effects of the inhalation of hydrogen fluoride: I. The response following exposure to high concentrations. J Ind Hyg 16:129–145.
MacLean DC, Schnieder RE. 1973. Fluoride accumulation by forage continuous vs intermittent exposures to hydrogen fluoride. J Environ Quart 2:501–503.
*Macuch P, Balazova G, Bartosova L, 1963. Hygienic analysis of the influence of noxious factors on the environment and state of health of the population in the vicinity of an aluminum plant. J Hyg Epidemiol Microbiol Immunol 7:389–403.
Macuch P, Kortus J, Balazova G, 1968. Effects of sodium and hydrogen fluorides on the metabolism of fluorine, calcium, and phosphorus in rats. Br J Ind Med 25:131–135.5647974
*Madans J, Kleinman JC, Cornoni-Huntley J. 1983. The relationship between hip fracture and water fluoridation: An analysis of national data. Am J Public Health 73:296–298.6824115
Maduska AL. 1980. Fluoride renal toxicity in fetus and neonate [letter]. Am J Obstet Gynecol 136:1080.
Maduska AL, Ahokas RA, Anderson GD, 1980. Placental transfer of intravenous fluoride in the pregnant ewe. Am J Obstet Gynecol 136:84–86.7188719
Mahadevan TN, Meenakshy V, Mishra UC. 1986. Fluoride cycling in nature through precipitation. Atmos Environ 20:1745–1750.
Maheshwari UR, King JC, Brunetti AJ, 1981. Fluoride balances in pregnant and nonpregnant women. J Occup Med 23:465–468.7252609
Maheshwari UR, King JC, Leybin L, 1983. Fluoride balances during early and late pregnancy. J Occup Med 25:587–590.6886867
Maheshwari UR, Schneider VS, McDonald JT, 1984. Relation of serum and urinary fluoride levels to fluoride intake in healthy men. Proc West Pharmacol Soc 27:469–473.6494187
*Mahoney MC, Nasca PC, Burnett WS, 1991. Bone cancer incidence rates in New York State: Time trends and fluoridated drinking water. Am J Public Health 81(4):475–479.2003628
Maier FJ. 1971. Fluoridation. Crit Rev Environ Control 2:387–430.
Makarov SV, Spitsyn VA, Kravchuk OI, 1999. Qualitative and quantitative variation of serum proteins in fluorosis patients. Russ J Genet 35(9):1125–1128.
Makhni SS, Singh P, Thapar SP. 1977. Long-term effects of fluoride administration: An experimental study: I. Radiological aspects. Fluoride 10:82–86.
*Malhotra A, Tweari A, Chawla HS, 1993. Placental transfer of fluoride in pregnant women consuming optimum fluoride in drinking water. J Indian Soc Pedod Prev Dent 11:1–3.8040692
*Mann J, Tibi M, Sgan-Cohen HD. 1987. Fluorosis and caries prevalence in a community drinking above-optimal fluoridated water. Community Dent Oral Epidemiol 15:293–295.3477364
*Manocha SH, Warner H, Olkowski BL. 1975. Cytochemical responses of kidney, liver, and nervous system to fluoride ions in drinking water. Histochem J 7:343–355.1150482
*Manoguerra AS, Neuman TS. 1986. Fatal poisoning from acute hydrofluoric acid ingestion. Am J Emerg Med 4:362–363.3718630
*Marais JS C. 1944. Monofluoracetic acid, the toxic principle of "grifblaar" Dichapetabum cymosum (Hook) Engl. Onderstepoort J Vet Sci Anim Indust 20:67–73.
Margolis HC, Moreno EC. 1990. Physicochemical perspectives on the cariostatic mechanisms of systemic and topical fluorides. J Dent Res 69(special issue):606–13.2179321
*Marie PJ, Hott M. 1986. Short-term effects of fluoride and strontium on bone formation and resorption in the mouse. Metabolism 35:547–551.3713515
Marier JR. 1977. Some current aspects of environmental fluoride. Sci Total Environ 8:253–266.918653
*Marks TA, Schellenberg D, Metzler CM, 1984. Effect of dog food containing 480 ppm fluoride on rat reproduction. J Toxicol Environ Health 14:707–714.6520882
Markuson KE. 1947. The use of sodium fluoride in the manufacture of steel. Industrial Medicine 16:434–436.
*Marquis RE. 1990. Diminished acid tolerance of plaque bacteria caused by fluoride. J Dent Res 69(special issue):672–5.2138181
Marshall BS, Wood R. 1968. A simple field test for the determination of hydrogen fluoride in air. Analyst 93:821–826.5728091
Marthaler TM. 1979. Fluoride supplements for systemic effects in caries prevention. In: Johansen E, Taves DR, Olsen TO, eds. Continuing evaluation of the use of fluorides. Boulder, CO: Westview. American Association for the Advancement of Science selected symposium no. 11, 33–59.
*Martin GR, Brown KS, Matheson DW, 1979. Lack of cytogenetic effects in mice or mutations in Salmonella receiving sodium fluoride. Mutat Res 66:159–167.372798
Masironi R. 1969. Trace elements and cardiovascular diseases. Bull WHO 40:305–312.4895656
*Masters RD, Coplan MJ, Hone BT, 2000. Association of silicofluroide treated water with elevated blood level. Neurotoxicology 21(6):1091–1099 11233755
Matsuno K. 1996. The treatment of hydrofluoric acid burns. Occup Med 46(4):313–317.
*Maupomé G, Clark DC, Levy SM, 2001. Patterns of dental caries following the cessation of water fluoridation. Commun Dent Oral Epidemiol 29:37–47.
*Maurer JK, Cheng MC, Boysen BG, 1990. 2-Year carcinogenicity study of sodium fluoride in rats. J Nat Cancer Inst 82(13):1118–1126.2359138
Maurer JK, Cheng MC, Boysen BG, 1993. Confounded carcinogenicity study of sodium fluoride in CD-1 mice. Regul Toxicol Pharmacol 18:154–168.8278638
*Maurer RL, Day HG. 1957. The non-essentiality of fluorine in nutrition. J Nutr 62:561–573.13449646
Maxwell JA, Caffrey JL, Yorio T, 1983. Fluoride-induced changes in renal papillary cyclic-AMP. Toxicol Appl Pharmacol 69:138–142.6304940
*Mayer TG, Gross PL. 1985. Fatal systemic fluorosis due to hydrofluoric acid burns. Ann Emerg Med 14:149–153.3970400
*Maylin GA, Krook L. 1982. Milk production of cows exposed to industrial fluoride pollution. J Toxicol Environ Health 10:473–478.6891000
Maylin GA, Eckerlin RH, Krook L. 1987. Fluoride intoxication in dairy calves. Cornell Vet 77:84–98.3802832
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
*McCann HG, Bullock FA. 1957. The effects of fluoride ingestion on the composition and solubility of mineralized tissues of the rat. J Dent Res 36:391–398.13428896
*McClure FJ. 1949. Fluorine in foods. Public health reports. U.S. Public Health Service. Public Health Reports 64:1061–1074.18140157
*McClure FJ. 1950. Availability of fluorine in sodium fluoride vs. sodium fluosilicate. Public Health Reports 65:1175–1186.14776180
*McClure FJ, Likins RC. 1951. Fluorine in human teeth studied in relation to fluorine in the drinking water. J Dental Res 30:172–176.
McClure FJ, Mitchell HH. 1931a. The effect of calcium fluoride and phosphate rock on the calcium retention of young growing pigs. J Agric Res 42:363–373.
McClure FJ, Mitchell HH. 1931b. The effect of fluorine on the calcium metabolism of albino rats and the composition of the bones. J Biol Chem 90:297–320.
McClure FJ, Zipkin I. 1958. Physiologic effects of fluoride as related to water fluoridation. In: Burket LW, ed. Dental clinics of North America. Philadelphia, PA: W.B. Saunders, 441–458.
*McClure FJ, Mitchell HH, Hamilton TS, 1945. Balances of fluorine ingested from various sources in food and water by five young men. J Ind Hyg Toxicol 27:159–170.
*McCulley JP, Whiting DW, Petitt MG, 1983. Hydrofluoric acid burns of the eye. J Occup Med 25:557–450.
McCune DC. 1971. Problems involved in devising air quality criteria for the effects of fluorides on vegetation. Am Ind Hyg Assoc J 32:697–701.5136842
*McDonagh MS, Whiting PF, Wilson PM, 2000. Systematic review of water fluoridation. Br Med J 321:855–859.11021861
*McGarvey CJ, Ernstene AC. 1947. Skeletal changes in chronic fluorine intoxication. Cleve Clin Q 14:108–112.20291352
McGown EL, Suttie JW. 1977. Mechanism of fluoride-induced hyperglycemia in the rat. Toxicol Appl Pharmacol 40:83–90.867434
McGown EL, Suttie JW. 1979. Central nervous system mediation of fluoride hyperglycemia in the rat. Toxicol Appl Pharmacol 48:205–211.473170
*McGuire SM, Vanable ED, McGuire JA, 1991. Is there a link between fluoridated water and osteosarcoma? J Am Dent Assoc 122:38–45.
*McIvor ME, Cummings CC, Mower MM, 1985. The manipulation of potassium efflux during fluoride intoxication: Implications for therapy. Toxicology 37:233–239.3907018
McIvor ME, Cummings CE, Mower MM, 1987. Sudden cardiac death from acute fluoride intoxication: The role of potassium. Ann Emerg Med 16:777–781.3592332
McLaren JR. 1976. Possible effects of fluorides on the thyroid. Fluoride 9:105–116.
McNally WD. 1923. Four deaths caused by sodium fluoride. JAMA 81:811.
Meador MC, Bethea RM. 1970. Syringe sampling technique for individual colorimetric analysis of reactive gases. Environ Sci Technol 4:853–855.
*Melton JR, Hoover WL, Ayers JL. 1974. Known addition procedure for determining fluoride in feeds with an ion-specific electrode. J Assoc Off Anal Chem 57:508–510.4833386
*Menchel SM, Dunn WA. 1984. Hydrofluoric acid poisoning. Am J Forensic Med Pathol 5:245–248.6496437
Mernagh JR, Harrison JE, Hancock R, 1977. Measurement of fluoride in bone. Int J Appl Radiat Isot 28:582–583.
*Messer HH, Ophaug RH. 1993. Influence of gastric acidity on fluoride absorption in rats. J Dent Res 72(3):619–622.8383710
*Messer HH, Armstrong WD, Singer L. 1973. Influence of fluoride intake on reproduction in mice. J Nutr 103:1319–1326.4725719
Meunier PJ, Courpron P, Smoller JS, 1980. Niflumic acid-induced skeletal fluorosis: Iatrogenic disease or therapeutic perspective for osteoporosis? Clin Orthop 148:304–309.
*Michael M, Barot VV, Chinoy NJ. 1996. Investigations of soft tissue functions in fluorotic individuals of north Gujarat. Fluoride 29(2):63–71.
*Mihashi M, Tsutsui T. 1996. Clastogenic activity of sodium fluoride to rat vertebral body-derived cells in culture. Mutat Res 368:7–13.8637511
Milan AM, Waddington RJ, Embery G. 2001. Fluoride alters casein kinase II and alkaline phosphatase activity in vitro with potential implications for dentine mineralization. Arch Oral Biol 46:343–351.11269868
*Milham S. 1979. Mortality in aluminum reduction plant workers. J Occup Med 21(7):475–480.469612
*Miller GW, Shupe JL, Vedina OT. 1999. Accumulation of fluoride in plants exposed to geothermal and industrial water. Fluoride 32(2):74–83.
*Miller RF, Phillips PH. 1955. The enhancement of the toxicity of sodium fluoride in the rat by high dietary fat. J Nutr 56:447–454.13252439
Minoguchi G. 1970. Japanese studies on water and food fluoride and general and dental health. In: Fluorides and human health. Geneva, Switzerland: World Health Organization, Series 59, 294–304.
*Miszke A, Sanokowska E, Winiarski J, 1984. Nasal septum and mucosa in fluorosis. Fluoride 17(2):114–118.
Mittal RL, Sidhu SS, Khokhar SS. 1987. Role of copper in skeletal changes in fluorosis: An experimental study in rabbits. Fluoride 20:104–108.
Modly CE, Burnett JW. 1987. Dermatologic manifestations of fluoride exposure. Cutis 40:89–90.2957175
Mohamed AH, Chandler ME. 1982. Cytological effects of sodium fluoride on mice. Fluoride 15:110–118.
Mohamed AH, Kemner PA. 1969. Cytogenetic effects of hydrogen fluoride on Drosophila-melanogaster. Genetics 61:541–542.
Mohamed AH, Applegate HG, Smith JD. 1966. Cytological reactions induced by sodium fluoride in allium cepa root-tip chromosomes. Can J Genet Cytol 8:241–244.
Molina MJ. 1981. Chemistry of fluorine in the stratosphere [Abstract]. 182nd ACS National Meeting, New York, NY, USA, August 23–28, 1981. Abstracts of Papers/American Chemical Society 182:30.
*Moller PF, Gudjonsson SV. 1932. Massive fluorosis of bones and ligaments. Acta Radiol 13:269–294.
Monsour PA, Kruger BJ, Petrie AF, 1984. Acute fluoride poisoning after ingestion of sodium fluoride tablets. Med J Aust 141:503–505.6482796
Monsour PA, Kruger BJ, Smid JR. 1985. Effects of a single intravenous dose of sodium fluoride on plasma electrolyte and metabolites in rats, rabbits, and cockerels. J Dent Res 64:1281–1285.3867685
*Morgan DP. 1989. Recognition and management of pesticide poisonings. Fourth edition. Washington, DC: U.S. Environmental Protection Agency. EPA-540/9–88-001.
*Morgan L, Allred E, Tavares M, 1998. Investigation of the possible associations between fluorosis, fluoride exposure, and childhood behavior problems. Pediatr Dent 20(4):244–252.9783294
Mörnstad H, van Dijken J. 1982. Caries preventive doses of fluoride and cyclic AMP levels in human plasma. Caries Res 16:277–281.6288242
*Morris JB, Smith FA. 1982. Regional deposition and absorption of inhaled hydrogen fluoride in the rat. Toxicol Appl Pharmacol 62:81–89.7064158
*Morris JB, Smith FA. 1983. Identification of two forms of fluorine in tissues of rats inhaling hydrogen fluoride. Toxicol Appl Pharmacol 71:383–390.6658788
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Morshina TN. 1980. Fluorine adsorption by soils. Soviet Soil Science 12:413–416.
Morshina TN, Fanaskova TP. 1985. Changes in soil properties caused by fluorine. Soviet Soil Science 17:74–79.
Moudgil A, Srivastava RN, Vasudev A, 1986. Fluorosis with crippling skeletal deformities. Indian J Pediatr 23:767–773.
Muehlberger CW. 1930. Toxicity studies of fluorine insecticides. J Pharmacol Exper Therap 39:246–248.
*Mueller WH. 1994. Sodium fluoride. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. 4^th^ Edition, Vol. 11. New York, NY: John Wiley and Sons, 426–428.
Mukherjee RN, Sobels FH. 1968. The effects of sodium fluoride and iodoacetamide on mutation by x-irradiation in mature spermatozoa of Drosophila. Mutat Res 6:217–225.5714160
*Mullenix PJ, Denbesten PK, Shunior A, 1995a. Neurotoxicity of sodium fluoride in rats. Neurotoxicol Teratol 17(2):169–177.7760776
Mullenix PJ, Denbesten PK, Schunior A, 1995b. Reply. Neurotoxicol Teratol 17(6):687–688.
*Mullet T, Zoeller T, Bingham H, 1987. Fatal hydrofluoric acid cutaneous exposure with refractory ventricular fibrillation. J Burn Care Rehabil 8:216–219.3649345
Murakami T, Nakagaki H, Sakakibara Y, 1987. The distribution pattern of fluoride concentrations in human cementum. Arch Oral Biol 32:567–571.3479098
Murer EH. 1976. Effects of fluoride on blood platelets. Fluoride 9:173–184.
*Murray JJ. 1993. Efficacy of preventive agents for dental caries. Systemic fluorides: water fluoridation. Caries Res 27(suppl 1):2–8.8500120
*Murray MM, Wilson DC. 1948. Fluorosis and nutrition in Morocco: Dental studies in relation to environment. Br Dental J 84:97–100.
Murty GV, Viswanathan TS, Ramakrishna V. 1957. Estimation of fluorine in microgramme quantities: A modified procedure. Anal Chim Acta 16:213–215.
*Myers HM. 1978. Fluorides and dental fluorosis. Monogr Oral Sci 7:1–76.277779
Naidu MR, Sastry KY, Reddy DR. 1986. Skeletal fluorosis, secondary to occult renal disease. Fluoride 19:166–168.
*Najjar VA. 1948. The isolation and properties of phosphoglucomutase. J Biol Chem 175:281–290.18873303
Najjar VA. 1963. Phosphoglucomutase. In: Boyer PD, Lardy H, Myrback K, eds. The enzymes. Vol. VI. New York, NY: Academic Press, 161–178.
*Narayana MV, Chinoy NJ. 1994. Effect of fluoride on rat testicular steroidogenesis. Fluoride 27(1):7–12.
*NAS. 1971a. Biologic effects of atmospheric pollutants: Fluorides. Washington, DC: National Academy of Sciences, National Research Council, Committee on Biologic Effects of Atmospheric Pollutants, 239.
NAS. 1971b. Guides for short-term exposures of the public to air pollutants: III. Guide for gaseous hydrogen fluoride. Committee on Toxicology. Washington, DC: National Academy of Sciences. APTD-0765, NTIS-PB203–465, 16.
*NAS/NRC. 1989. Biologic markers in reproductive toxicity. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
Nash TH, Gries C. 1995. The use of lichens in atmospheric deposition studies with an emphasis on the Arctic. Sci Total Environ 160/161:729–736.
NATICH. 1989. National Air Toxics Information Clearinghouse. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards.
Navia JM, Aponte-Merced L, Punyasingh K. 1988. Fluoride metabolism in humans. Essential and Toxic Trace Elements in Human Health and Disease 18:229–250.
*NCI. 1978. Bioassay of acronycine for possible carcinogenicity. Bethesda, MD: National Institutes of Health, NCI Carcinogenesis Technical Report Series No. 49, 152.
Neal C. 1989. Fluorine variations in Welsh streams and soil waters. Sci Total Env 80:213–223.
Nedeljkovic M, Matovic V. 1991. The effect of dose on maternal-foetal transfer of fluoride in rabbits. Arh Hig Rada Toksikol 42:43–46.1854264
*Needleman HL, Pueschel SM, Rothman KJ. 1974. Fluoridation and the occurrence of Down's syndrome. N Engl J Med 291:821–823.4278945
Neefus JD, Cholak J, Saltzman BE. 1970. The determination of fluoride in urine using a fluoride-specific ion electrode. Am Ind Hyg Assoc J 96–99.5437810
Nelson RL. 1987. Dietary minerals and colon carcinogenesis (review). Anticancer Res 7:259–269.3296940
*Neuberger JS. 1982. Fluoridation and cancer. J Kans Med Soc 83:134–139.7077117
*Neuman WI, Neuman MW, Mair EK, 1950. The surface chemistry of bone: II. Fluoride deposition. J Biol Chem 187:655–661.14803448
Newbrun E. 1987. Topical fluoride therapy: Discussion of some aspects of toxicology, safety, and efficacy. J Dent Res 66:1084–1086.3475327
NHMRC Australia. 1991. The effectiveness of water fluoridation. Canberra, Australia: Department of Health, Housing and Community Services, National Health and Medical Research Council.
*Nicolli HB, Suriano JM, Gomez Peral MA, 1989. Groundwater contamination with arsenic and other trace elements in an area of the Pampa, province of Cordoba, Argentina. Environ Geol Water Sci 14(1):3–16.
Nielsen HM. 1960. The determination of fluoride in soft tissue, bone, and urine. Arch Indust Health 21:316–317.
NIOSH. 1975. Criteria for a recommended standard: Occupational exposure to inorganic fluorides. Cincinnati, OH: U.S. Department of Health, Education, and Welfare. Public Health Service. Center for Disease Control. National Institute for Occupational Safety and Health. DHEW publication no. (NIOSH)76–103.
NIOSH. 1976a. Criteria for a recommended standard: Occupational exposure to hydrogen fluoride. Cincinnati, OH: U.S. Department of Health, Education, and Welfare. Public Health Service. Center for Disease Control. National Institute for Occupational Safety and Health. DHEW publication no. (NIOSH) 76–143.
NIOSH. 1976b. National occupational hazard survey. Department of Health and Human Services. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1984a. National occupational exposure survey (1980–1983). Cincinnati, OH: National Institute for Occupational Safety and Health. Department of Health and Human Services.
NIOSH. 1984b. NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: Division of Physical Sciences and Engineering. National Institute for Occupational Safety and Health.
NIOSH. 1985. NIOSH pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services. National Institute for Occupational Safety and Health. DHHS (NIOSH) publication no. 85–114.
NIOSH. 1987. National occupational hazard survey. Cincinnati, OH: National Institute for Occupational Safety and Health. Department of Health and Human Services.
*NIOSH. 1989. National occupational exposure survey (1980–1983). Cincinnati, OH: National Institute for Occupational Safety and Health. Department of Health and Human Services.
NIOSH. 1990a. NIOSH manual of analytical methods. Division of Laboratories and Criteria Development. Cincinnati, OH: National Institute for Occupational Safety and Health, U.S. Department of Health, Education and Welfare. Centers for Disease Control, 329.
NIOSH. 1990b. NIOSH pocket guide to chemicals hazards. Washington, DC: U.S. Department of Health and Human Services. Center for Disease Control. National Institute for Occupational Safety and Health. Division of Standard Development and Technology Transfer. NIOSH publication no. 90–117.
*NIOSH. 1994. NIOSH Manual of Analytical Methods. 4th ed. Cincinnati, OH: Division of Physical Sciences and Engineering.
*NIOSH. 2001a. NIOSH pocket guide to chemical hazards. Fluorine. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0289.html. March 27, 2001.
*NIOSH. 2001b. NIOSH pocket guide to chemical hazards. Hydrogen fluoride. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0334.html. March 27, 2001.
*NIOSH. 2001c. NIOSH pocket guide to chemical hazards. Sodium fluoride. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0563.html. March 27, 2001.
NIOSH/OSHA. 1978. Occupational health guidelines for chemical hazards. Cincinnati, OH: National Institute for Occupational Safety and Health/Occupational Safety and Health Administration.
*Nopakun J, Messer HH. 1989. Fluoride absorption from the gastrointestinal tract of rats. J Nutr 119:1411–1417.2585131
*Nopakun J, Messer HH. 1990. Mechanism of fluoride absorption from the rat small intestine. Nutr Res 10:771–779.
Nopakun J, Guo MK, Messer HH, 1988. Fluoride redeposition and retention during bone turnover in lactating rats. J Dent Res 67:1213–1216.3166003
Nordlund AL, Ekstrand JL, Hammarstrom L. 1986. Fluorine-induced cystic changes in the enamel organ of the rat molar. J Oral Pathol 15:87–92.3083068
NRC. 1977a. Drinking water and health: Part I. Chapters 1–5: A report of the safe water drinking committee. Washington, DC: The National Research Council. National Academy of Sciences. Safe Drinking Water Committee. Advisory Center on Toxicology Assembly of Life Sciences. PB-270 422.
NRC. 1977b. Drinking water and health: Part II. Chapters 6 and 7: A report of the safe water drinking committee. Washington, DC: The National Research Council. National Academy of Sciences. Safe Drinking Water Committee. Advisory Center on Toxicology Assembly of Life Sciences. PB-270 423.
*NRC. 1982. Water chemicals codex. Committee on Water Treatment Chemicals. Food and Nutrition Board, Assembly of Life Sciences. National Research Council. Washington, DC. National Academy Press.
NRC. 1989. Recommended dietary allowances. 10th ed. Subcommittee on the Tenth Edition of the RDAs Food and Nutrition Board, Commission on Life Sciences. National Research Council. National Academy of Science. Washington, DC: National Academy Press, 235–239.
*NRC. 1993. Health Effects of Ingested Fluoride. Commission on Life Sciences, National Research Council. Washington, DC: National Academy Press, 51–72; 125–128. http://www.nap.edu/books/030904975X/html/.
*NRC Canada. 1971. Environmental fluoride 1971. Ottawa, Ontario: National Research Council of Canada, NRCC Associate Committee on Scientific Criteria for Environmental Quality. NRC pub. No. 12226.
NRC Canada. 1977. Environmental fluoride, 1977. Ottawa, Ontario: National Research Council of Canada, NRC Associate Committee on Scientific Criteria for Environmental Quality. NRCC no. 16081.
*NTP. 1990. NTP technical report on the toxicology and carcinogenesis studies of sodium fluoride in F344/N Rats and B6C3F1 mice (drinking water studies). Washington, DC: Department of Health, Education, and Welfare, National Toxicology Program. NTP TR 393, NIH publication no. 90–2848.
Ockerse T. 1941. Endemic fluorosis in the Kenhardt and Gordonia districts, Cape Province, South Africa. J Am Dent Assoc 28:936–941.
*Oelschälger W. 1971. Fluoride uptake in soil and its depletion. Fluoride 4:80–84
Øgaard B, Seppa L, Rǿlla G. 1994. Professional topical fluoride applications – clinical efficacy and mechanism of action. Adv Dent Res 8(1):190–201.7865075
*Oguro A, Cervenka J, Horii K-I. 1995. Effect of sodium fluoride on chromosomal ploidy and breakage in cultured human diploid cells (IMR-90): An evaluation of continuous and short-time treatment. Pharmacol Toxicol 76:292–296.7617562
O'Hara JP, Fraser AJ, James MP. 1982. Superphosphate poisoning of sheep: The role of fluoride. N Z Vet J 30:199.16030846
*Okushi I. 1971. Experimental studies on the effects of sodium fluoride upon the heart muscle of rabbits. Fluoride 4(4):199–203.
*Oldham PD, Newell DJ. 1977. Fluoridation of water supplies and cancer. Applied Statistics 26:125–135.
*Oliveby A, Lagerlōf F, Ekstrand J, 1989. Studies on fluoride concentrations in human submandibular/sublingual saliva and their relation to flow rate and plasma fluoride levels. J Dent Res 68(2):146–149.2918136
Oliveby A, Twetman S, Ekstrand J. 1990. Diurnal fluoride concentration in whole saliva in children living in a high- and a low-fluoride area. Caries Res 24:44–47.
Olmez I, Sheffield AE, Gordon GE, 1988. Compositions of particles from selected sources in Philadelphia for receptor modeling applications. J Air Pollut Control Assoc 38(11):1392–1402.
Olszewska E, Kilbery B, Luker M. 1978. Sodium fluoride and mutagenesis in neurospora. Mutat Res 53:245–246.
Omueti JA, I., Jones RL. 1977. Regional distribution of fluorine in Illinois U.S.A soils. Scientific Society of America-Journal 41:771–774.
Ophaug RH, Singer L, Harland BF. 1980a. Estimated fluoride intake of 6-month-old infants in four dietary regions of the United States. Am J Clin Nutr 33:324–327.7355802
Ophaug RH, Singer L, Harland BF. 1980b. Estimated fluoride intake of average two-year-old children in four dietary regions of the United States. J Dent Res 59(5):777–781.6928866
*Ophaug RH, Singer L, Harland BF. 1985. Dietary fluoride intake of 6-month and 2-year-old children in four dietary regions of the United States. Am J Clin Nutr 42:701–707.4050730
*Opinya GN, Bwibo N, Valderhaug J, 1991a. Intake of fluoride through food and beverages by children in a high fluoride (9 ppm) area in Kenya. Discov Innov 3(4):71–75.
Opinya GN, Bwibo N, Valderhaug J, 1991b. Intake of fluoride and excretion in mothers' milk in a high fluoride (9 ppm) area in Kenya. Eur J Clin Nutr 45(1):37–42.1855498
OSHA. 1982. Occupational Safety and Health Administration. Federal Register 47:30420.
*OSHA. 1985. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000
OSHA. 1989. Air contaminants. Occupational Safety and Health Administration. Federal Register 54:2332–2983.
*OSHA. 2001a. Air contaminants. Shipyards. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1915.1000, Table Z. http://www.osha-slc.gov/OshStd_data/1915_1000.html (http://www.osha/-slc.gov/OshStd_data/1915_1000.html). March 26, 2001.
*OSHA. 2001b. General requirements. Welding, cutting, and brazing. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1910.252 (c)(1). http://www.osha-slc.gov/OshStd_data/1910_0252.html. March 26, 2001.
OSHA. 2001c. Limits for air contaminants. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1910.1000, Table Z-1. http://www.osha-slc.gov/OshStd_data/1910_1000_Table_Z-1.html (http://www.osha/-slc.gov/OshStd_data/1910_1000_Table_Z-1.html). March 26, 2001.
*OSHA. 2001d. List of highly hazardous chemicals, toxics and reactives (mandatory). Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1910.119, Appendix A. http://www.osha-slc.gov/OshStd_data/1910_0119_APP_A.html. March 26, 2001.
*OSHA. 2001e. List of highly hazardous chemicals, toxics and reactives (mandatory). Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1926.64, Appendix A. http://www.osha-slc.gov/OshStd_data/1910_0119_APP_A.html. March 26, 2001.
*OSHA. 2001f. Threshold limit values of airborne contaminants for construction. Occupational Safety and Health Administration. U.S. Department of Labor. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha-slc.gov/OshStd_data/1926_0055_APP_A.html. March 26, 2001.
Otey MG, Pulley H. 1973. Determination of gaseous fluorine in air. Am Ind Hyg Assoc J 34:418–420.4752277
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Pader M. 1993. Dentifrices. In: Kirk-Othmer, encyclopedia of chemical technology. New York, NY: John Wiley and Sons, 1023–1030.
*Pak CY C, Sakhaee K, Adams-Huet B, 1995. Treatment of postmenopausal osteoporosis with slow-release sodium fluoride. Final report of a randomized controlled trial. Ann Intern Med 123:401–408.7639438
Pak CY C, Sakhaee K, Zerwekh JE, 1989. Safe and effective treatment of osteoporosis with intermittent slow release sodium fluoride: Augmentation of vertebral bone mass and inhibition of fractures. J Clin Endocrinol Metab 68(1):150–159.2909549
*Pandit CG, Raghavachari TN S, Rao DS, 1940. Endemic fluorosis in South India: A study of the factors involved in the production of mottled enamel in children and severe bone manifestations in adults. Indian J Med Res 28:533–558.
*Pang DT Y, Phillips CL, Bawden JW. 1992. Fluoride intake from beverage consumption in a sample of North Carolina children. J Dent Res 71(7):1382–1388.1629454
Pang YX, Guo YQ, Fu KW, 1996. The effects of fluoride, alone and in combination with selenium, on the morphology and histochemistry of skeletal muscle. Fluoride 29(2):59–62.
Pantucek MB. 1975. Hygiene evaluation of exposure to fluoride fume from basic arc-welding electrodes. Ann Occup Hyg 18:207–212.1217792
*Parker CM, Sharma Rap, Shupe JL. 1979. The interaction of dietary vitamin C, protein and calcium with fluoride: Effects in guinea pigs in relation to breaking strength and radiodensity of bone. Clin Toxicol 15:301–312.509894
Parker PR, Bawden JW. 1986. Prenatal fluoride exposure: Measurement of plasma levels and enamel uptake in the guinea pig. J Dent Res 65:1341–1345.3478394
Parkins FM, Greenlimb PE. 1974. Fluoride secretion in rat bile during periods of intestinal fluoride absorption. J Dent Res 53:1296.4529468
Pashley DJ, Allison NB, Easmann RP, 1984. The effects of fluoride on the gastric mucosa of the rat. J Oral Pathol 13:535–545.6434719
Pasquini R, Scassellati-Sforzolini G, Angeli G, 1996. Cytogenetic biomonitoring of pesticide-exposed farmers in central Italy. J Environ Pathol Toxicol Oncol 15(1):29–39.9037262
Patel D, Milind VS, Narayana MV, 1994. Effects of sodium fluoride on physiology of female mice and its reversal. Proc Acad Environ Biol 3(2):197–205.
*Pati PC, Buhnya SP. 1987. Genotoxic effect of an environmental pollutant, sodium fluoride, in mammalian in vivo test system. Caryologia 40:79–88.
Pattee OH, Wiemeyer SN, Swineford DM. 1988. Effects of dietary fluoride on reproduction in eastern screech-owls. Arch Environ Contam Toxicol 17:213–218.
*Paul V, Ekambaram P, Jayakumar AR. 1998. Effects of sodium fluoride on locomotor behavior and a few biochemical parameters in rats. Environ Toxicol Pharmacol 6:187–191.21781893
Penman AD, Brackin BT, Embrey R. 1997. Outbreak of acute fluoride poisoning caused by a fluoride overfeed, Mississippi, 1993. Public Health Rep 112:403–409.9323392
*Perkinson JD, Whitney TB, Monroe RA, 1955. Metabolism of fluorine-18 in domestic animals. Am J Physiol 182:383–389.13258819
Peters D, Miethchen R. 1996. Symptoms and treatment of hydrogen fluoride injuries. J Fluorine Chem 79:161–165.
*Peters RA, Shorthouse M, Murray LR. 1964. Biochemistry: Enolase and fluorophosphate. Nature 202:1331–1332.14210967
Petersen LR, Denis D, Brown D, 1988. Community health effects of a municipal water supply hyperfluoridation accident. Am J Public Health 78(6):711–713.3369608
*Petersson LG, Ludvigsson N, Ullbro C, 1987. Fluoride clearance of whole saliva in young school children after topical application. Swed Dent J 11:95–101.3477027
Petraborg HT. 1974. Chronic fluoride intoxication from drinking water (preliminary report). Fluoride 7:47–52.
Pettyjohn WA. 1975. Pickling liquors, strip mines, and ground-water pollution. Ground Water 13:4–11.
Phillips PH, Lamb AR, Hart EB, 1933. Studies on fluorine in the nutrition of the rat: II. Its influence on reproduction. Am J Physiol 106:356–364.
Phipps KR, Burt BA. 1990. Water-borne fluoride and cortical bone mass: A comparison of two communities. J Dent Res 69(6):1256–1260.2355118
*Phipps KR, Orwoll ES, Bevan L. 1998. The association between water-borne fluoride and bone mineral density in older adults. J Dent Res 77(9):1739–1748.9759671
*Phipps KR, Orwoll ES, Mason JD, 2000. Community water fluoridation, bone mineral density, and fractures: Prospective study of effects in older women. Br Med J 321:860–864.11021862
Pillai KS, Mathai AT, Deshmukh PB. 1987. Acute toxicity of fluoride to mice. Fluoride 20:68–70.
*Pillai KS, Mathai AT, Deshmukh PB. 1988. Effect of subacute dosage of fluoride on male mice. Toxicol Lett 44:21–30.3188078
Pitt MJ. 1982. A vapor hazard index for volatile chemicals. Chem Ind 20:804–806.
Pitter P. 1985. Forms of occurrence of fluorine in drinking water. Water Res 19:281–284.
Pohlandt K, Strecker M, Marutzky R. 1993. Ash from the combustion of wood treated with inorganic wood preservatives: Element composition and leaching. Chemosphere 26(12):2121–2128.
Polomski J, Fluehler H, Blaser P. 1982. Accumulation of airborne fluoride in soils. J Environ Qual 11:457–461.
*Poulsen OM, Christensen JM, Sabbioni E, 1994. Trace element reference values in tissues from inhabitants of the European Community. V. Review of trace elements in blood, serum and urine and critical evaluation of reference values for the Danish population. Sci Total Environ 141:197–215.8178120
Poulsen S, Moller IJ, Naerum J, 1972. Prevalence of dental caries in 2383 Moroccan school children aged eight and twelve. Arch Oral Biol 17:1165–1175.4403568
Powell WA, Saylor JH. 1953. Fluorimetric determination of small amounts of fluoride. Anal Chem 25:960–964.
Purdell-Lewis DJ, Suckling GW, Triller M, 1987. Artificially induced developmental defects in sheep enamel examined by scanning electron microscopy. J Biol Buccale 15:119–124.3479426
Purohit SD, Gupta RC, Mathur AK, 1999. Experimental pulmonary fluorosis. Indian J Chest Dis Allied Sci 41(1):27–34.10639761
Rajan KS, Raisen E, Mandler JW, 1976. Improved fluoride incorporation and new in vitro fluorine elemental determination. J Dent Res 55:671.1064614
*Rao GS. 1984. Dietary intake and bioavailability of fluoride. In: Darby WJ, ed. Annual review of nutrition. Palo Alto, CA: Annual Reviews Inc., 115–136.
*Rao HV, Beliles RP, Whitford GM, 1995. A physiologically based pharmacokinetic model for fluoride uptake by bone. Regulat Toxicol Pharmacol 22:30–42.
*Rao SH, Gopal ER, Raj R. 1969. A case of acute sodium fluoride (sic) intoxication. J Assoc Physicians India 17:373–374.5381341
Rao US, Murthy SK. 1991. The effects of β-mercaptoethanol and sodium dodecyl sulfate on the humicola insolens β-glucosidase. Biochem Int 23(2):343–348.1907139
*Rapaport I. 1956. Contribution a l’etude du mongolism, role pathogenique du fluor. Bulletin de l’Academie Nationale Medecine (Paris) 140:525–531.
Rastogi R, Upreti RK, Kidwai AM. 1987a. Alteration in gastric enzymes of rats following in situ administration of sodium fluoride. Fluoride 20:71–74.
Rastogi R, Upreti RK, Kidwai AM. 1987b. Effect of fluoride on the intestinal epithelial cell brush border membrane. Bull Environ Contam Toxicol 39:162–167.2955821
Ream LJ, Principato R. 1981. Glycogen accumulation in the parathyroid gland of the rat after fluoride ingestion. Cell Tissue Res 220:125–130.7273122
*Ream LJ, Scott JN, Pendergrass PB. 1983. Bone morphology of weanling rats from dams subjected to fluoride. Cell Tissue Res 233:689–691.6627356
Reddy GS, Rao BS. 1972. Effect of fluoride on the skeleton of rats maintained on different levels of calcium in the diet. Indian J Med Res 60:481–487.4659927
*Reddy GS, Srikantia SG. 1971. Effect of dietary calcium, Vitamin C, and protein in development of experimental skeletal fluorosis: I. Growth, serum chemistry, and changes in composition and radiological appearance of bones. Metabolism 20:642–649.4996890
Reddy J, Grobler SR, Reiter NF. 1988. The relationship of the periodontal status to fluoride levels of alveolar bone and tooth roots. J Clin Periodontol 15:217–221.3164330
Reeves TG. 1996. Technical aspects of water fluoridation in the United States and an overview of fluoridation engineering world-wide. Commun Dent Health 13(Suppl 2):21–26.
Refsnes M, Becher R, Lag M, 1999. Fluoride-induced interleukin-6 nad interleukin-8 synthesis in human epithelial. Hum Exp Toxicol 18(11):645–652.10602388
*Reimann C, De Caritat P, Halleraker JH, 1997. Rainwater composition in eight arctic catchments in Northern Europe (Finland, Norway and Russia). Atmos Environ 31(2):159–170.
Retief DH, Bradley EL, Barbakow FH, 1979. Relationships among fluoride concentration in enamel, degree of fluorosis and caries incidence in a community residing in a high fluoride area. J Oral Pathol 8:224–236.115980
Retief DH, Harris BE, Bradley EL. 1987. Relationship between enamel fluoride concentration and dental caries experience. Caries Res 21:68–78.3466709
Retief DH, Summerlin, Harris BE, 1985. An evaluation of three procedures for fluoride analysis. Caries Res 19:248–254.3857988
Reynolds KE, Whitford GM, Pashley DH. 1978. Acute fluoride toxicity: The influence of acid-base status. Toxicol Appl Pharmacol 45:415–428.30184
Ricca PM. 1970. A survey of the acute toxicity of elemental fluorine. Am Ind Hyg Assoc J 31:22–29.4908743
*Richards A, Fejerskov O, Ekstrand J. 1982. Fluoride pharmacokinetics in the domestic pig. J Dent Res 61:1099–1102.6963284
*Richards A, Kragstrup J, Nielsen-Kudsk F. 1985. Pharmacokinetics of chronic fluoride ingestion in growing pigs. J Dent Res 64:425–430.3855893
Richmond VL. 1985. Thirty years of fluoridation: A review. Am J Clin Nutr 41:129–138.3917599
Rigalli A, Ballina JC, Beinlich AD, 1994. Pharmacokinetic differences between sodium fluoride and sodium monofluorophosphate and comparative bone mass increasing activity of both compounds in the rat. Arzneim Forsch 44:762–766.8053977
*Rigalli A, Morosano M, Puche RC. 1996. Bioavailability of fluoride administered as sodium fluoride or sodium monofluorophosphate to human volunteers. Arzneim Forsch 46(1):531–533.8737641
*Riggs BL, Hodgson SF, O'Fallon WH, 1990. Effect of fluoride treatment on the fracture rate in postmenopausal women with osteoporosis. N Engl J Med 322:802–809.2407957
*Riggs BL, O’Fallon WM, Lane A, 1994. Clinical trial of fluoride therapy in postmenopausal osteoporotic women: Extended observations and additional analysis. J Bone Min Res 9:265–75.
Rioufol C, Bourbon P, Philibert C. 1982. Histology and biochemistry of renal parenchyma in guinea-pigs due to long-term exposure to hydrogen fluoride. Fluoride 15:157–161.
*Ripa LW. 1993. A half-century of community water fluoridation in the United States: review and commentary. J Public Health Dent 53:17–44.8474047
Rippel A, Janovitcova J. 1971. The effect of fluorine exhalates on the flora in the surroundings of an aluminum plant. Ten Houten, JG (chairman) Air Pollution. Proceedings of the 1st European Congress on the Influence of Air Pollution on Plants and Animals. Wageningen, The Netherlands, 173–178.
*Roberts JR, Merigian KS. 1989. Acute hydrofluoric-acid exposure. Am J Emerg Med 7:125–126.2914038
*Robinson WO, Edgington G. 1946. Fluorine in soils. Soil Sci 61: 341–353.
*Rockette HE, Arena VC. 1983. Mortality studies of aluminum reduction plant workers: Potroom and carbon department. J Occup Med 25(7):549–557.6886861
*Rogot E, Sherrett AR, Feinleib M, 1978. Trends in urban mortality in relation to fluoridation status. Am J Epidemiol 107:104–112.623093
*Roholm K. 1937. Macroscopic examination of bones. In: Fluorine intoxication. A clinical-hygienic study. HK Lewis & Co., Ltd., London, England, 180–210.
*Rölla G, Ekstrand J. 1996. Fluoride in oral fluids and dental plaque. In: Fejerskov O, Ekstrand J, Burt BA, eds. Fluoride in dentistry. 2nd ed. Copenhagen: Munksgaard, 215–229.
Rom WN, Barkman H. 1983. Respiratory irritants. Environ Occup Med 273–283.
Ron M, Singer L, Menczel J, 1986. Fluoride concentration in amniotic fluid and fetal cord and maternal plasma. Eur J Obstet Gynecol Reprod Biol 21:213–218.3709921
Rope SK, Arthur WJ, Craig TH, 1988. Nutrient and trace elements in soil and desert vegetation of Southern Idaho. Environ Monit Assess 10:1–24.24248523
*Rosen S, Frea JI, Hsu SM. 1978. Effect of fluoride-resistant microorganisms on dental caries. J Dent Res 57:180.277510
Rosenholtz MJ, Ford DF. 1962. Pathologic observations in animals after single, brief exposures to hydrogen fluoride. Edgewood Arsenal, MD: U.S. Army Chemical Research and Development Laboratories. CRDLR 3158.
*Rosenholtz MJ, Carson TR, Weeks MH, 1963. A toxicopathologic study in animals after brief single exposures to hydrogen fluoride. Am Ind Hyg Assoc J 24:253–261.13974949
*Rosenquist JB, Lorentzon PR, Boquist LL V. 1983. Effect of fluoride on parathyroid activity of normal and calcium-deficient rats. Calcif Tissue Int 35:533–537.6616320
Ross JF, Daston GP. 1995. To the Editor. Neurotoxicol Teratol 17(6):685–686.8747751
Rowley RJ, Farrah GH. 1962. Diffusion method for determination of urinary fluoride. Am Ind Hyg Assoc J 23:314–318.14494675
*Rubin ES. 1999. Toxic releases from power plants. Environ Sci Technol 33:3062–3067.
*Rudolph H, Kraushaar JJ, Ristinen RA, 1973. Determination of trace amounts of fluoride by nuclear inelastic scattering. Trace Subst Environ Health 7:387–393.
Ruzicka JA, Mrklas L, Rokytova K. 1984. Split-dose administration of fluoride in mice versus incorporation and fluorosis. Pharmazie 39:349.6473497
Rwenyonyi CM, Birkeland JM, Haugejorden O. 2000. Age as a determinant of severity of dental fluorosis in children residing in areas with 0.5 and 2.5 mg fluoride per liter in drinking water. Clin Oral Investig 4(3):157–161.
*Rye WA. 1961. Fluorides and phosphates -- clinical observations of employees in phosphate operation. International Congress on Occupational Health, July 25–29, 1960, 361–364.
Saady JJ, Rose CS. 1988. A case of nonfatal sodium fluoride ingestion. J Anal Toxicol 12:270–271.3226123
Sadilova MS, Petina AA. 1971. Hygienic significance of low fluorine concentrations for different routes of intake. Hyg Sanit 35:181–187.
*Sadilova MS, Selyankina KP, Shturkina OK. 1965. Experimental studies on the effect of hydrogen fluoride on the central nervous system. Hyg Sanit 30:155–160.
*Sager M. 1987. Rapid-determination of fluorine in solid samples. Monatsh Chem 118:25–29.
Sakama H. 1980. Toxicological studies of fluorine compounds: 1. Acute toxicity of sodium fluoride to rats and mice in relation to age, sex, animal genus and administration route. Shikwa Gakuho 80:1519–1529.
Sandberg D, Zichner L. 1985. A case of bone fluorosis of undetermined origin. Arch Orthop Trauma Surg 104(3):191–5.4062523
*San Filippo FA, Battistone GC. 1971. The fluoride content of a representative diet of the young adult male. Clin Chim Acta 31:453–457.5108307
Sanz-Gallèn P, Noguè S, Munnè P, 2001. Hypocalcaemia and hypomagnesaemia due to hydrofluoric acid. Occup Med 51(4):294–295.
*Saralakumari D, Ramakrishna Rao PR. 1993. Endemic fluorosis in the village Ralla Anantapuram in Andhra Pradesh: An epidemiological study. Fluoride 26(3):177–180.
Saralakumari D, Rao PR. 1991. Red blood cell glucose metabolism in human chronic fluoride toxicity. Bull Environ Contam Toxicol 47:834–839.1786454
Saric M, Zuskin E, Gomzi M. 1979. Bronchoconstriction in potroom workers. Br J Ind Med 36:211–215.
Sato T, Yoshitake K, Hitomi G. 1986. Mechanism of fluoride absorption from the gastrointestinal tract in rats. Stud Environ Sci 27:325–332.
*Sauerbrunn BJ L, Ryan CM, Shaw JF. 1965. Chronic fluoride intoxication with fluorotic radiculomyelopathy. Ann Intern Med 63:1074–1078.5844566
*Sauriol A, Gauthier B. 1984. Study of Industrial Fluoride: Four Canadian Cases. Vol. 2. Conseil Consultatif de L’environnement, Québec, Canada (December 1984).
Savas S, Cetin M, Akdoğan M. 2001. Endemic fluorosis in Turkish patients: relationship with knee osteoarthritis. Rheumatol Int 21:30–35.11678300
Saxena VK, Ahmed S. 2001. Dissolution of fluoride in groundwater: a water-rock interaction study. Environ Geol 40:1084–1087.
*Schamschula RG, Sugar E, Agus HM, 1982. The fluoride content of human tooth enamel in relation to environmental exposure to fluoride. Aust Dent J 27:243–247.6960864
*Schamschula RG, Sugar E, Un PS H, 1985. Physiological indicators of fluoride exposure and utilization: An epidemiological study. Community Dent Oral Epidemiol 13:104–107.3857144
Schenk GH, Dilloway KP. 1969. Determination of fluoride by fluorescence quenching. Anal Lett 2:379–385.
*Schick AL. 1973. Determination of fluoride in household products by ion selective electrode and Gran's plot. J Assoc Off Anal Chem 56:798–802.
*Schiffl HH, Binswanger U. 1980. Human urinary fluoride excretion as influenced by renal functional impairment. Nephron 26:69–72.7412962
*Schiffl HH, Binswanger U. 1982. Renal handling of fluoride in healthy man. Renal Physiol 5:192–196.7122982
Schiffl H, Hofmann U, Huggler M, 1981. Renal fluoride excretion: Experimental evaluation of the role of extracellular volume status during intact and impaired kidney function. Nephron 29:245–249.7322252
*Schlesinger ER,Overton DE, Chase HC. 1956. Newburgh-Kingston caries fluorine study XIII. Pediatric findings after ten years. J Am Dent Assoc 52:296–306.13294993
Schnitzer-Polokoff R, Suttie JW. 1981. Effect of fluoride on the absorption of dietary fat in rats. J Nutr 111:537–544.7205406
Schulz JA, Lamb AR. 1925. The effect of fluorine as sodium fluoride on the growth and reproduction of albino rats. Sci 61:93–94.
*Schwarz K, Milne DB. 1972. Fluorine requirement for growth in the rat. Bioinorg Chem 1:331–338.
Scott EW, Henne AL. 1935. Titration of fluorine in biological materials. Ind Engin Chem 7:299–300.
*Selwitz RH, Nowjack-Raymer RE, Kingman A, 1995. Prevalence of dental caries and dental fluorosis in areas with optimal and above-optimal water fluoride concentrations: a 10-year follow-up study. J Public Health Dent 55(2):85–93.7643332
*Seixas NS, Cohen M, Zevenbergen B, 2000. Urinary fluoride as an exposure index in aluminum smelting. Am Ind Hyg Assoc J 61:89–94.
*Seppä L, Kärkkäinen S, Hausen H. 2000. Caries trends 1992–1998 in two low-fluoride Finnish towns formerly with and without fluoridation. Caries Res 34:462–468.11093019
*Setchell BP, Waites GM H. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
*Seyb ST, Noordhoek L, Botens S, 1995. A study to determine the efficacy of treatments for hydrofluoric acid burns. J Burn Care Rehab 16:253–257.
*Shacklette HT, Boerngen JG. 1984. Element concentrations in soils and other surficial materials of the conterminous United States. Washington, DC. U.S. Department of the Interior. Geological Survey Professional Paper 1270.
*Shacklette HT, Boerngen JG, Keith JR. 1974. Selenium, fluorine, and arsenic in surficial materials of the conterminous United States. Washington, DC: U.S. Department of the Interior. Geological Survey Circular 692.
Shahed AR, Miller A, Chalker D, 1979. Effect of sodium fluoride on cyclic AMP production in rat hepatocytes. J Cyclic Nucleotide Res 5:43–53.220288
*Sharkey TP, Simpson WM. 1933. Accidental sodium fluoride poisoning: Report of eight cases, with one fatality. JAMA 100(2):97–100.
Sharma YD. 1982. Variations in the metabolism and maturation of collagen after fluoride ingestion. Biochim Biophys Acta 715:137–141.7074130
Shashi. 1988. Biochemical effects of fluoride on thyroid gland during experimental fluorosis. Fluoride 21:127–130.
Shayiq RM, Raza H, Kidwai AM. 1986. Effects of fluoride on membrane permeability and brush border enzymes of rat intestine in situ. Food Chem Toxicol 24:33–36.2868974
Shchori D, Gedalia I, Nizel AE, 1976. Fluoride uptake in rats given tea with milk. J Dent Res 55:916.1067311
*Shearer TR. 1974. Comparative metabolic responses of rat kidneys and liver to acute doses of fluoride. Proc Soc Exper Biol Med 146:209–212.4827252
Shearer TR, Ridlington JW. 1976. Fluoride-selenium interaction in the hard and soft tissues of the rat. J Nutr 106:451–456.1255264
*Shellenberg D, Marks TA, Metzler CM, 1990. Lack of effect of fluoride on reproductive performance and development in Shetland sheepdogs. Vet Hum Toxicol 32(4):309–314.2389542
*Shen Y-W, Taves DR. 1974. Fluoride concentrations in the human placenta and maternal and cord blood. Am J Obstet Gynecol 119:205–207.4823388
Shi J, Dai G, Zhang Z. 1995. Relationship between bone fluoride content, pathological change in bone of aborted fetuses and maternal fluoride level. Chin J Prev Med 29(3):103–105.
*Shia G. 1994. Fluorine. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. 4^th^ Edition, Vol. 11. New York, NY: John Wiley and Sons, 241–267.
*Shida N, Matsushima K, Wada M. 1986. A new method for analyzing the distribution of fluoride in human enamel. J Nihon Univ Sch Dent 28:61–76.3012018
*Shimonovitz S, Patz D, Ever-Hadani P, 1995. Umbilical cord fluoride serum levels may not reflect fetal fluoride status. J Perinat Med 23:279–282.8537857
*Shroy RE, Kraner HW, Jones KW, 1982. Proton activation analysis for the measurement of fluorine in food samples. Anal Chem 54:407–413.
*Shulman ER, Vallejo M. 1990. Effect of gastric contents on the bioavailability of fluoride in humans. Pediatric Dentistry 12(4):237–240.2077500
*Silva MJ, Ulrich SR. 2000. In vitro fluoride exposure decreases torsional and bending strength and increases ductility of mouse femora. J Biomech 33:231–234.10653038
Silverman DM, Taves DR. 1981. The distribution of fluoride and calcium in the liver of the carbon tetrachloride-poisoned rat. Toxicol Appl Pharmacol 61:172–176.7324063
*Simonen O, Laitinen O. 1985. Does fluoridation of drinking-water prevent bone fragility and osteoporosis? Lancet 2:432–434.2863455
Simpson A, Shaw L, Smith AJ. 2001. The bio-availability of fluoride from black tea. J Dent 29:15–21.11137634
Simpson E, Shankara Rao LG, Evans RM, 1980. Calcium metabolism in a fatal case of sodium fluoride poisoning. Ann Clin Biochem 17:10–14.7377741
Singer L, Armstrong WD. 1954. Determination of fluoride procedure based upon diffusion of hydrogen fluoride. Anal Chem 26:904–906.
Singer L, Armstrong WD. 1959. Determination of fluoride in blood serum. Anal Chem 31:105–109.
Singer L, Ophaug R. 1982. Ionic and nonionic fluoride in plasma (or serum). CRC Crit Rev Clin Lab Sci 18:111–140.
Singer L, Ophaug RH. 1979. Concentrations of ionic, total, and bound fluoride in plasma. Clin Chem 25:523–525.466759
Singh A, Jolly SS. 1970. Chronic toxic effects on the skeletal system. In: Fluorides and human health. Geneva, Switzerland: World Health Organization Monographs, Series 59, 238–249.
*Singh A, Jolly SS, Bansal BC, 1963. Endemic fluorosis: Epidemiological, clinical and biochemical study of chronic fluorine intoxication in Punjab (India). Medicine 42:229–246.13977630
Singh M. 1984. Biochemical and cytochemical alterations in liver and kidney following experimental fluorosis. Fluoride 17:81–93.
*Skare JA, Schrotel KR, Nixon GA. 1986. Lack of DNA-strand breaks in rat testicular cells after in vivo treatment with sodium fluoride. Mutat Res 170:85–92.3960046
*Skjelkvale BL. 1994. Factors influencing fluoride concentrations in Norwegian Lakes. Water Air Soil Pollut 77:151–167.
Skolnick A. 1990. New doubts about benefits of sodium fluoride. JAMA 263:1752–1753.2179588
*Skoog DA, West DM, Holler JF. 1990. Analytical chemistry: An introduction. 5^th^ edition. Harcourt Brace Jovanovich College Publishers, 343–5, 440–1, 506–8.
*Slameňova D, Gavelova A, Ruppova K. 1992. Cytotoxicity and genotoxicity testing of sodium fluoride on Chinese hamster V79 cells and human EUE cells. Mutat Res 279:109–115.1375335
Slameňova D, Ruppova K, Gabelova A, 1996. Evaluation of mutagenic and cytotoxic effects of sodium fluoride on mammalian cells influenced by an acid environment. Cell Biol Toxicol 12:11–17.8882385
*Slater EC, Bonner WD. 1952. The effect of fluoride on the succinic oxidase system. Biochem J 52:185–196.13018205
*Smith AH. 1980. An examination of the relationship between fluoridation of water and cancer mortality in 20 large U.S. cities. N Z Med J 91(661):413–416.6930028
Smith FA, ed. 1966. Pharmacology of fluorides. In: Eichler O, Farah A, Herken H, , eds. Handbook of experimental pharmacology. 20(1):1–500.
Smith FA. 1971. Biological monitoring guides: Fluorides. Am Ind Hyg Assoc J 32:274–279.
Smith FA, Gardener DE. 1949. Effect of renal dysfunction on the urinary excretion of fluoride in the rabbit. Fed Proc 8:333.
Smith FA, Hodge HC. 1979. Airborne fluorides and man: Part I. CRC Crit Rev Environ Control 8:293–371.
Smith FA, Gardner DE, Hodge HC. 1953. Age increase in fluoride content in human bone. Fed Proc 12:368.
*Smith FA, Gardner DE, Leone N, 1960. The effects of the absorption of fluoride. AMA Arch Ind Health 21:330–332.13831958
Smith GE. 1985a. Fluoride and bone: An unusual hypothesis. Xenobiotica 15(3):177–186.4024655
Smith GE. 1985b. Toxicity of fluoride-containing dental preparations: A review. Sci Total Environ 43:41–61.3892685
Smith GE. 1986. Fluoride, the environment, and human health. Perspect Biol Med 29 (Summer):560–572.3748771
Smith GE. 1988a. Fluoride and fluoridation. Soc Sci Med 26:451–462.3283946
Smith GE. 1988b. Genotoxic effects of fluoride and implications for its use in the treatment of osteoporosis. N Z Med J 101:213.
Smith GE. 1988c. Is fluoride a mutagen? Sci Total Environ 68:79–96.3283934
Smith QT, Armstrong WD, Singer L. 1959. Inhibition of human salivary and prostatic acid phosphatase and yeast enolase by low fluoride concentrations. Proc Soc Exper Biol Med 102:170–173.13832122
*Smith RA. 1994. Fluorine. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. 4^th^ Edition, Vol. 11. New York, NY: John Wiley and Sons, 355–376.
Snow GR, Anderson C. 1985. Short-term chronic fluoride administration in beagles: A pilot study. Bone 6:365–367.4096872
Snyder D, Walker WG, Whelton A. 1973. Acute toxic drug ingestions at the Johns Hopkins Hospital 1963–1970. Johns Hopkins Med J 132:157–167.4691171
Sondhi H, Gupta ML, Gupta GL. 1995. Effects of sodium fluoride on Swiss albino mice. Geobios 22:18–21.
*Sowers MF R, Clark MK, Jannausch ML, 1991. A prospective study of bone mineral content and fracture in communities with differential fluoride exposure. Am J Epidemiol 133:649–660.2018020
*Sowers MF R, Wallace RB, Lemke JH. 1986. The relationship of bone mass and fracture history to fluoride and calcium intake: A study of three communities. Am J Clin Nutr 44:889–898.3788836
*Söyseth V, Kongerud J, Ekstrand J, 1994. Relation between exposure to fluoride and bronchial responsiveness in aluminum potroom workers with work-related asthma-like symptoms. Thorax 49:984–989.7974315
*Spak C-J, Berg U, Ekstrand J. 1985. Renal clearance of fluoride in children and adolescents. Pediatrics 75:575–579.3975128
*Spak CJ, Ekstrand J, Eriksson S, 1986. Distribution of fluoride to the central nervous system. Caries Res 20:157.
Spak C-J, Hardell LI, DeChateau P. 1983. Fluoride in human milk. Acta Paediatr Scand 699–701.6685423
*Spak C-J, Sjöstedt S, Eleborg L, 1989. Tissue response of gastric mucosa after ingestion of fluoride. Brit Med J 298:1686–1687.2503177
*Spak C-J, Sjostedt S, Eleborg L, 1990. Studies of human gastric mucosa after application of 0.42% fluoride gel. J Dent Res 69(2):426–429.2307744
Speaker JH. 1976. Determination of fluoride by scientific ion electrode and report of a fatal case of fluoride poisoning. Forensic Sci 21:121–126.
Speirs RL. 1986. The relationship between fluoride concentrations in serum and in mineralized tissues in the rat. Arch Oral Biol 31:373–381.3463264
*Spencer H, Lender M. 1979. Adverse effects of aluminum-containing antacids in mineral metabolism. Gastroenterology 76:603.428714
Spencer H, Kramer L, Gatza CA, 1978a. Fluoride mineral interactions in man. Physiologist 21:114.
*Spencer H, Kramer L, Gatza CA, 1980a. Fluoride metabolism in patients with chronic renal failure. Arch Intern Med 140:1331–1335.7425768
Spencer H, Kramer L, Osis D, 1975b. Excretion of retained fluoride in man. J Appl Physiol 38:282–287.1120753
Spencer H, Kramer L, Osis D, 1980b. Effect of calcium, phosphorus, magnesium, and aluminum on fluoride metabolism in man. Ann NY Acad Sci 355:181–194.6940475
Spencer H, Kramer L, Wiatrowski E, 1977a. Magnesium-fluoride interrelationships in man: I. Effect of fluoride on magnesium metabolism. Am J Physiol 233:E165–169.910903
Spencer H, Kramer L, Wiatrowski E, 1978b. Magnesium-fluoride interrelationships in man. II. Effect of magnesium on fluoride metabolism. Am J Physiol 234:E343–347.645849
*Spencer H, Lewin I, Wistrowski E, 1970. Fluoride metabolism in man. Am J Med 49:807–813.5006619
Spencer H, Osis D, Kramer L, 1975c. Effect of calcium and phosphorus on fluoride metabolism in man. J Nutr 105:733–740.1142003
*Spencer H, Osis D, Lender M. 1981. Studies of fluoride metabolism in man: A review and report of original data. Sci Total Environ 17:1–12.7010597
Spencer H, Osis D, Wiatrowski E, 1975d. Plasma levels and excretion of fluoride in relation to fluoride intake in man. Trace Substances in Environmental Health 8:299–304.
Spencer H, Osis D, Wiatrowski E. 1975a. Retention of fluoride with time in man. Clin Chem 21:613–618.1116298
Spencer H, Wiatrowski E, Osis D, 1977b. Magnesium-fluoride interrelationships in man. Trace Substances in Environmental Health 10:389–394.
*Spoerke DG, Bennett DL, Gullekson DJ. 1980. Toxicity related to acute low dose sodium fluoride ingestions. J Fam Pract 10:139–140.7350253
*Sprando RL, Collins TF X, Black T, 1998. Testing the potential of sodium fluoride to affect spermatogenesis: A morphometric study. Food Chem Toxicol 36:1117–1124.9862654
*Sprando RL, Collins TF X, Rorie BJ, 1997. Testing the potential of sodium fluoride to affect spermatogenesis in the rat. Food Chem Toxicol 35:881–890.9409628
Sqewielow A. 1991. Wydalanie fluoru w moczu i kale szczurow w zaleznosci od zrodla tego pier wiastka i zawartosci bialka w diecie. Rocz Panstw Zakl Hig 42(4):415–421.1844016
*SRI. 2002. 2002 Directory of chemical producers: United States of America. Menlo Park, CA: Stanford Research Institute International, 641, 643, 662, 871, 878.
*Stavert DM, Archuleta DC, Behr MF, 1991. Relative acute toxicities of hydrogen fluoride, hydrogen chloride, and hydrogen bromide in nose- and pseudo-mouth-breathing rats. Fundam Appl Toxicol 16:636–655.1653158
*Steichen J, Koelliker J, Grosh D, 1988. Contamination of farmstead wells by pesticides, volatile organics, and inorganic chemicals in Kansas. Ground Water Monit Rev 8(3):153–160.
*Stephen KW, McCall Dr, Tullis JL. 1987. Caries prevalence in northern Scotland before, and 5 years after water defluoridation. Br Dent J 163:324–326.3479992
Stevens BJ, Willis GL, Hemphrey TJ, 1987. Combined toxicity of aluminum and fluoride in the rat: Possible implications in hemodialysis. Trace Elements of Medicine 4:61–66.
*Stokinger HE. 1949. Toxicity following inhalation of fluorine and hydrogen fluoride. In: Voegtlin C, Hodge HC, eds. Pharmacology and toxicology of uranium compounds. New York, NY: McGraw Hill Book Company, 1021–1057.
Stokinger HE. 1981. The halogens and the nonmetals boron and silicon. In: Clayton GD, Clayton FE, eds. Patty's industrial hygiene and toxicology. Vol 2B:2937–2954.
Stokinger HE, Ashenburg WJ, DeVoldre J, 1950. Acute inhalation toxicity of beryllium: The enhancing effect of the inhalation of hydrogen fluoride vapor on beryllium sulfate poisoning in animals. Ind Hyg Occup Med 1:398.
*Stookey GK, Crane DB, Muhler JC. 1964. Further studies on fluoride absorption. Proc Soc Exper Biol Med 115:295–298.14121592
Stosser L, Heinrich R. 1985. Fluoride effect of calcium and phosphate content in femur of the pregnant rat and on calcium transfer through the placenta. Fluoride 18:216–220.
Strubelt O, Iven H, Younes M. 1982. The pathophysiological profiles of the acute cardiovascular toxicity of sodium fluoride. Toxicology 24:313–323.6927649
*Stumm W, Morgan JJ. 1981. Aquatic chemistry. 2^nd^ edition. New York: John Wiley and Sons, 365–367.
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 284–285.
*Suarez-Almazor ME, Flowerdew G, Saunders LD, 1993. The fluoridation of drinking water and hip fracture hospitalization rates in two Canadian communities. Am J Public Health 83(5):689–693.8484450
Suketa Y, Akiyama Y, Satoh Y, 1986. Effect of fluoride administration on glucose metabolism in rats. Fourth International Congress of Toxicology, Tokyo, Japan, July 21–25, 1986. Toxicol Lett 31:188.
Susheela AK. 1995. Epidemiological studies of health risks from drinking water naturally contaminated with fluoride. IAHS Publ 233:123–134.
*Susheela AK, Bhatnagar M. 2002. Reversal of fluoride induced cell injury through elimination of fluoride and consumption of diet rich in essential nutrients and antioxidants. Mol Cell Biochem 234/235:335–340.12162452
*Susheela AK, Das TK. 1988. Chronic fluoride toxicity: A scanning electron microscopic study of duodenal mucosa. J Toxicol Clin Toxicol 26:467–476.3230598
*Susheela AK, Jain SK. 1983. Fluoride-induced hematological changes in rabbits. Bull Environ Contam Toxicol 30:388–393.6850126
Susheela AK, Jethanandani P. 1994. Serum haptoglobin and c-reactive protein in human skeletal fluorosis. Clin Biochem 27(6):463–468.7697892
*Susheela AK, Jethanandani P. 1996. Circulating testosterone levels in skeletal fluorosis patients. Clin Toxicol 34(2):183–189.
*Susheela AK, Kumar A. 1991. A study of the effect of high concentrations of fluoride on the reproductive organs of male rabbits, using light and scanning electron microscopy. J Reprod Fertil 92:353–360.1886094
Susheela AK, Kumar A. 1997. Ultrastructural studies on the leydig cells of rabbits exposed to chronic fluoride toxicity. Environ Sci 5(2):79–94.
Susheela AK, Mukerjee D. 1981. Fluoride poisoning and the effect on collagen biosynthesis of osseus and non-osseus tissues of rabbit. Toxicological European Research 3:99–104.7245192
*Susheela AK, Das TK, Gupta IP, 1992. Fluoride ingestion and its correlation with gastrointestinal discomfort. Fluoride 25(1):5–22.
Suttie JW. 1980. Nutritional aspect of fluoride toxicosis. J Anim Sci 51:759–766.7440457
*Suttie JW, Phillips PW. 1959. The effect of age on the rats of fluorine deposition in the femur of the rat. Arch Biochem Biophys 83:355–359.13835839
Suttie JW, Hamilton RJ, Clay AC, 1985. Effects of fluoride ingestion on white-tailed deer (Odocoileus virginianus): Does fluoride affect developing immune system cells? J Wildl Dis 23:283–288.
Suttie JW, Phillips PH, Miller RF. 1958. Studies of the effects of dietary sodium fluoride on dairy cows: III. Skeletal and soft tissue fluorine deposition and fluorine toxicosis. J Nutr 65:293–304.13576214
Sutton PR N. 1986. Is fluorosis an etiological factor in overuse injuries (RSI)? Medical Hypotheses 21:369–371.3642204
Suzuki Y. 1979. The normal levels of fluorine in the bone tissue of Japanese subjects. Tohoku J Exp Med 129:327–336.524356
*Symonds RB, Rose WJ, Reed MH. 1988. Contribution of Cl- and F-bearing gases to the atmosphere by volcanoes. Nature 334:415–418.
Takagi M, Shiraki S. 1982. Acute sodium fluoride toxicity in the rat kidney. Bull Tokyo Med Dent Univ 29:123–130.6293730
*Takahashi K, Akiniwa K, Narita K. 2001. Regression analysis of cancer incidence rates and water fluoride in the U.S.A. based on IACR/IARC (WHO) data (1978–1992). J Epidemiol 11(4):170–179.11512573
Takamori T. 1955. Recent studies on fluorosis. Tokushima J Exp Med 2:25–44.
Tannenbaum A, Silverstone H. The genesis and growth of tumors: IV. Effects of varying the proportion of protein (casein) in the diet. Cancer Res 9:162–173.18113452
*Tao S, Suttie JW. 1976. Evidence for a lack of an effect of dietary fluoride level on reproduction in mice. J Nutr 106:1115–1122.939992
Tatevossian A. 1990. Fluoride in dental plaque and its effects. J Dent Res 69(special issue):645–652.2179325
Taves DR. 1966. Normal human serum fluoride concentrations. Nature 1:192–193.
*Taves DR. 1968. Determination of submicromolar concentrations of fluoride in biological samples. Talanta 15:1015–1023.18960400
*Taves DR. 1977. Fluoridation and cancer mortality. In: Origins of human cancer: Book A: Incidence of cancer in humans. Cold Spring Harbor Conferences on Cell Proliferation 4:357–366.
*Taves DR. 1978. Fluoridation and mortality due to heart disease. Nature 272:361–362.634362
Taves DR. 1979. Claims of harm from fluoridation. In: Johnson E, Taves DR, Olsen TO, eds. Continuing evaluation of the use of fluorides. American Association for the Advancement of Science-Selected Symposium, 11:295–321.
Taves DR, Guy WS. 1979. Distribution of fluoride among body compartments. AAAS Selected Symposium 11:159–185.
*Taves DR, Neuman WF. 1964. Factors controlling calcification in vitro: fluoride and magnesium. Arch Biochem Biophys 108:390–397.14244677
Taves DR, Terry R, Smith FA, 1965. Use of fluoridated water in long-term hemodialysis. Arch Intern Med 115:167–172.14331997
Taylor A. 1954. Sodium fluoride in the drinking water. Dent Dig 60:170–172.
Taylor A, Taylor NC. 1965. Effect of sodium fluoride on tumor growth. Proc Soc Exper Biol Med 119:252–255.14297862
*Ten Cate JM. 1999. Current concepts on the theories of the mechanism of action of fluoride. Acta Odontol Scand 57:325–329.10777135
Teotia M, Teotia SP, Singh RK. 1979a. Metabolism of fluoride in pregnant women residing in endemic fluorosis areas. Fluoride 12:58–64.
Teotia M, Teotia SP, Singh RK. 1979b. Skeletal fluoride toxicity in children. Indian J Pediatr 46:389–396.546756
Teotia SP, Teotia M. 1988. Endemic skeletal fluorosis: Clinical and radiological variants (Review of 25 years of personal research). Fluoride 21:39–44.
*Teotia SP, Teotia M. 1994. A disorder of high fluoride and low dietary calcium interactions (30 years of personal research). Fluoride 27:59–66.
Teotia SP, Teotia M, Singh RK, 1978. Plasma fluoride, 25-hydroxy-cholecalciferol, immunoreactive parathyroid hormone and calcitonin in patients with endemic skeletal fluorosis. Fluoride 12:115–119.
*Tepperman PB. 1980. Fatality due to acute systemic fluoride poisoning following a hydrofluoric-acid skin burn. J Occup Med 22:691–692.7431138
Theuer RC, Mahoney AW, Sarett HP. 1971. Placental transfer of fluoride and tin in rats given various fluoride and tin salts. J Nutr 101:525–532.5580072
*Thomas FD, Kossab JY, Jones BM. 1995. Fluoridation in Anglesey 1993: a clinical study of dental caries in 5-year old children who had experienced sub-optimal fluoridation. Br Dent J 178:55–59.7848757
Thompson DJ. 1980. Industrial considerations related to fluoride toxicity. J Anim Sci 51:767–772.7440458
*Thompson RJ, McMullen TB, Morgan GB. 1971. Fluoride concentrations in the ambient air. J Air Pollut Control Assoc 21:484–487.5563432
*Thomson EJ, Kilanowski FM, Perry PE. 1985. The effect of fluoride on chromosome aberration and sister-chromatid exchange frequencies in cultured human lymphocytes. Mutat Res 144:89–92.3930955
Thurman EM, Barber LB, LeBlanc D. 1986. Movement and fate of detergents in groundwater: A field study. J Contam Hydrol 1:143–161.
*Thylstrup A. 1990. Clinical evidence of the role of pre-eruptive fluoride in caries prevention. J Dent Res 69(special issue):742–50.2179336
*Thylstrup A, Fejerskov O. 1978. Clinical appearance and surface distribution of dental fluorosis in permanent teeth in relation to histological changes. Commun Dent Oral Epidemiol 6:329–337.
*Thylstrup A, Fejerskov O, Bruun C, 1979. Enamel changes and dental caries in 7-year-old children given fluoride tablets from shortly after birth. Caries Res 13:265–76.288511
Toler LG. 1967. Fluoride in water in the Alafia and Peace River basins, Florida. United States Geological Survey, State of Florida, State Board of Conservation, State of Florida 46:1–46.
Tong CC, McQueen CA, VedBrat S, 1986. The lack of genotoxicity of sodium fluoride (NAF) in an in vitro test battery. Environ Mutagen 8:86.
*Tong CC, McQueen CA, VedBrat S, 1988. The lack of genotoxicity of sodium fluoride in a battery of cellular tests. Cell Biol Toxicol 4:173–186.3233530
Topolewski P, Zommer-urbanska S. 1987. A new spectrophotometric method of determining fluoride by using the rutine-zirconium (IV) complex. Microchemical Journal 35:145–152.
Toth K, Sugar E, Bordacs I, 1978. Fluorine content of vegetables and fruits. Acta Physiol Acad Sci Hung 51:353–360.754476
Townsend D, Frey P, Jeavons A, 1987. High density avalanche chamber (HIDAC) positron camera. J Nucl Med 28:1554–1562.3498804
TPCDB. 1989. Testing Priority Committee Database. Washington, DC: U.S. Environmental Protection Agency.
Trautner K, Einwag J. 1986. Bioavailability of fluoride from some health food products in man. Caries Res 20:518–524.3465445
*Trautner K, Einwag J. 1987. Factors influencing the bioavailability of fluoride from calcium-rich, health food products and CaF_2_ in man. Arch Oral Biol 32(6):401–406.3479080
*Trautner K, Siebert G. 1986. An experimental study of bio-availability of fluoride from dietary sources in man. Arch Oral Biol 31(4):223–228.3459412
Treon JF, Dutra FR, Cappel J, 1950. Toxicity of sulfuric acid mist. AMA Archives of Industrial Hygiene and Occupational Medicine 2:716.14782734
*TRI01. 2003. TRI explorer. Providing access to EPA’s toxics release inventory data. Washington, DC. Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. http://www.epa.gov/triexplorer/. August 13, 2003.
Trivedi N, Mithal A, Gupta SK, 1993. Reversible impairment of glucose tolerance in patients with endemic fluorosis. Diabetologia 36:826–828.8405753
Tsuboi S, Nakagaki H, Takami Y, 2000. Magnesium and fluoride distribution in human cementum with age. Calcif Tissue Int 57:466–471.
Tsuchida M, Okayasu I, Teraoka K, 1991. The effect of prolonged ingestion of high levels (100 ppm) of fluorine on osseous tissues of rats. Environmental Sciences 1(2):63–72.
Tsunoda H, Sakurai S, Itai K, 1984. Normal urinary fluoride levels in Japanese subjects: Relationship between urinary fluoride levels and environmental fluoride. Fluoride 17:159–167.
Tsutsui T, Koichi I, Maizumi H. 1984a. Induction of unscheduled DNA synthesis in cultured human oral keratinocytes by sodium fluoride. Mutat Res 140:43–48.6738571
*Tsutsui T, Suzuki N, Ohmori M. 1984b. Sodium fluoride-induced morphological and neoplastic transformation, chromosome aberrations, sister chromatid exchanges, and unscheduled DNA synthesis in cultured Syrian hamster embryo cells. Cancer Res 44:938–941.6692416
*Tsutsui T, Suzuki N, Ohmori M, 1984c. Cytotoxicity, chromosome aberrations and unscheduled DNA synthesis in cultured human diploid fibroblasts induced by sodium fluoride. Mutat Res 199:193–198.
*Tsutsui T, Tanaka Y, Matsudo Y, 1995. No increases in chromosome aberrations in human diploid fibroblasts following exposure to low concentrations of sodium fluoride for long times. Mutat Res 335:15–20.7616984
Turkington RP. 1984. An inexpensive portable, multi-sampler. Am Ind Hyg Assoc J 45:B-18, B-20, B-22.
*Turner CH, Akhter MP, Heaney RP. 1992. The effects of fluoridated water on bone strength. J Orthop Res 10(4):581–587.1613632
*Turner CH, Boivin G, Meunier PJ. 1993. A mathematical model for fluoride uptake by the skeleton. Calcif Tissue Int 52:130–138.8443689
*Turner CH, Garetto LP, Dunipace AJ, 1997. Fluoride treatment increased serum IGF-1, bone turnover, and bone mass, but not bone strength, in rabbits. Calcif Tissue Int 61:77–83.9192519
Turner CH, Hasegaw K, Zhang W, 1995. Fluoride reduces bone strength in older rats. J Dent Res 74(8):1475–1481.7560402
*Tusl J. 1970. Direct determination of fluoride in human urine using fluoride electrode. Clin Chim Acta 27:216–218.5412607
Underwood EJ. 1971. Fluorine. In: Trace elements in human and animal nutrition. New York, NY: Academic Press, 369–406.
*Urbansky ET. 2002. Fate of fluorosilicate drinking water additives. Chem Rev 102:2837–2853.12175269
Urbansky ET, Schock MR. 2000. Can fluoridation affect lead(II) in potable water? Hexafluorosilicate and fluoride equilibria in aqueous solution. Int J Environ Studies 57:597–637.
*USC. 2001. Hazardous air pollutants. U.S. Code. 42 USC 4712. http://www4.law.cornell.edu/uscode/42/7412.text.html. March 27, 2001.
USGS. 1984. Element concentrations in soils and other surficial materials of the conterminous United States. Washington, DC: United States Government Printing Office, U.S. Geological Survey.
USGS. 1999b. Minerals Yearbook 1999. Fluorspar. U.S. Geological Survey http://minerals.usgs.gov/minerals/pubs/commodity/fluorspar/280499.pdf. April 19, 1999.
*USGS. 2001. Commodity Summaries. Fluorspar. U.S. Geological Survey http://minerals.usgs.gov/minerals/pubs/commodity/fluorspar/280301.pdf. March 16, 2001.
*USGS. 2002a. Mineral commodity summary. Fluorspar. U.S. Geological Survey. http://minerals.usgs.gov/minerals/publ/commodity/fluorspar/280302.pdf.
*USGS. 2002b. Mineral yearbook. Fluorspar. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/fluorspar/280401.pdf.
*Uslu B. 1983. Effect of fluoride on collagen synthesis in the rat. Res Exp Med 182:7–12.
Usuda K, Kono K, Dote T, 1999. Usefulness of the assessment of urinary enzyme leakage in monitoring acute fluoride nephrotoxicity. Arch Toxicol 73(6):346–351.10447562
Van de Putte M, De Cock J, Dryon L, 1977. A contribution to the study of fluoride excretion. Clin Chim Acta 75:205–212.844205
Van Der Hoeven JS, Franken HC M. 1984. Effect of fluoride on growth and acid production by streptococcus-mutans in dental plaque. Infect Immun 45:356–359.6746094
*Van Hook C. 1974. Fluoride distribution in the Silverbow, Montana area. Fluoride 7:181–199.
Van Leuven HC E. 1970. Organic multi-element analysis with a small mass spectrometer as detector: A preliminary note. Anal Chim Acta 49:364–366.
Van Loveren C. 1990. The antimicrobial action of fluoride and its role in caries inhibition. J Dent Res 69(special issue):676–681.2179329
Van Rensberg SW J, de Vos WH. 1966. The influence of excess fluorine intake in the drinking water on reproductive efficiency in bovines. Ondersepoort J Vet Res 33(1):185–194.
Van Rensburg BG. 1979. Metabolism of fluorides. Tydskr Tandheelkd Ver S Afr 34:163–166.397629
Varadacharyulu NC, Rao PR. 1997. Gluconeogenesis and glycogenolysis in fluoride-treated rats. Indian J Exp Biol 35:906–908.9475069
*Varner JA, Jensen KF, Horvath W, 1998. Research report: Chronic administration of aluminum--fluoride or sodium–fluoride to rats in drinking water: Alterations in neuronal and cerebrovascular integrity. Brain Res 784:284–298.9518651
Venkateswarlu P. 1974. Reverse extraction technique for the determination of fluoride in biological materials. Anal Chem 46:879–882.
Venkateswarlu P, Sita P. 1971. New approach to the microdetermination of fluoride: Adsorption diffusion technique. Anal Chem 43:758–760.5122631
*Venkateswarlu P, Singer L, Armstrong WD. 1971. Determination of ionic (plus ionizable) fluoride in biological fluids. Anal Biochem 42:350–359.5118579
Vernot EH, MacEwen JD, Haun CC, 1977. Acute toxicity and skin corrosion data for some organic and inorganic compounds and aqueous solutions. Toxicol Appl Pharmacol 42:417–423.595018
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
VIEW. 1989. Agency for Toxic Substances and Disease Registry (ATSDR). Division of Health Studies, Atlanta, GA. September 25, 1989.
*Villa A, Anabalŏn M, Cabezas L. 2000. The fractional urinary fluoride excretion in young children under stable fluoride intake conditions. Commun Dent Oral Epidemiol 28:344–355.
Villee CA. 1984. Birth defects and glycolysis. N Engl J Med 310:254–255.6690941
*Vine MF. 1994. Biological markers: Their use in quantitative assessments. Adv Dent Res 8(1):92–99.7993566
*Vischer TL, Bernheim C, Guerdjikoff C, 1970. Industrial fluorosis. In: Visher TL, ed. Fluoride in medicine, 96–105.
Vogel E. 1973. Strong antimutagenic effect of fluoride on mutation induction by trenimon and 1-phenyl-3,3-dimethyltriazene in Drosophila melanogaster. Mutat Res 20:339.4205056
*Vogel GL, Carey CM, Chow LC, 1990. Fluoride analysis in nanoliter- and microliter-size fluid samples. J Dent Res. 69:522–528.2312891
*Vogel GL, Carey CM, Ekstrand J. 1992a. Distribution of fluoride in saliva and plaque fluid after a 0.048 mol/L NaF rinse. J Dent Res. 71(9):1553–1557.1522286
*Vogel GL, Mao Y, Carey CM, 1992b. In vivo fluoride concentrations measured for two hours after a NaF or a novel two-solution rinse. J Dent Res. 71(3):448–452.1573075
Vogt RL, Witherell L, LaRue D, 1982. Acute fluoride poisoning associated with an on-site fluoridator in a Vermont elementary school. Am J Public Health 72:1168–1169.7114344
Von Tirpitz C, Klaus J, Bruckel J, 2000. Increase of bone mineral density with sodium fluoride in patients with Crohn's disease. Eur J Gastroenterol Hepatol 12:19–24.10656205
*Voroshilin SI, Plotko EG, Nikiforova VY A. 1975. Mutagenic effect of hydrogen fluoride on animals. Tsitol Genet 9:40–42.
Wagner MJ, Stookey CK, Muhler K. 1958. Deposition of fluoride in soft tissue following skeletal saturation. Proc Soc Exper Biol Med 99:102–105.13601781
Waitrowski E, Kramer L, Osis D, 1975. Dietary fluoride intake of infants. Pediatrics 55(4):517–522.1173283
Waldbott GL. 1955. Chronic fluoride intoxication from drinking water. Int Arch Allergy 7:70–74.13262897
Waldbott GL. 1961. The physiologic and hygienic aspects of the absorption of inorganic fluorides. Arch Environ Health 2:69–81.
Waldbott GL. 1963a. Acute fluoride intoxication. Acta Med Scand 174(Suppl.):1–44.14042463
*Waldbott GL. 1963b. Fluoride in food. Am J Clin Nutr 12:455–462.13998426
Waldbott GL. 1971. Chronic fluoride intoxication due to air pollution. In: Englund HM, ed. Proceedings of the Second International Clean Air Congress. 2nd ed., 151–155.
*Waldbott GL. 1979. Pre-skeletal neighborhood fluorosis: An epidemic near an Ohio enamel smelter. Vet Hum Toxicol 21:140–144.505940
*Waldbott GL. 1981. Mass intoxication from accidental overfluoridation of drinking water. Clin Toxicol 18:531–541.7023807
Waldbott GL. 1998. The preskeletal phase of chronic fluoride intoxication. Fluoride 31(1):13–20.
*Waldbott GL, Lee JR. 1978. Toxicity from repeated low-grade exposure to hydrogen fluoride: Case report. Clin Toxicol 13:391–402.743869
*Wallace-Durbin P. 1954. The metabolism of fluorine in the rat using F^18^ as a tracer. J Dent Res 33:789–800.13211872
Walton KC. 1987. Fluoride in bones of small rodents living in areas with different pollution levels. Water Air Soil Pollut 32:113–122.
*Walton KC. 1988. Environmental fluoride and fluorosis in mammals. Mammal Rev 18:77–90.
Wang J, Zheng ZA, Zhang LS, 1993. An experimental study for early diagnostic features in fluorosis. Fluoride 26(1):61–65.
Wang Y, Yin Y, Gilula LA, 1994. Endemic fluorosis of the skeleton: Radiographic features in 127 patients. Am J Roentgenol 162:93–98.8273699
Wang Y-N, Xiao K-Q, Liu J-L, 2000. Effect of long term fluoride exposure on lipid composition in rat liver. Toxicology 146:161–169.10814848
*Ward PF V, Hall RJ, Peters RA. 1964. Fluoro-fatty acids in the seeds of Dichapetabum toxicarium. Nature 201:611–612.
Warneke G, Setnikar I. 1993. Effects of meal on the pharmacokinetics of fluoride from oral monofluorophosphate. Arzneim Forsch 43(1):590–595.8329005
*Warren JJ, Levy SM. 1999. A review of the fluoride dentifrice related to dental fluorosis. Pediatric Dent 21(4):265–271.
*Watanabe M, Yoshida Y, Watanabe M, 1975. Effect of hydrofluoric acid on glucose metabolism of the mouse studied by whole-body autoradiography. Br J Ind Med 32:316–320.1201258
*Waterhouse C, Taves D, Munzer A. 1980. Serum inorganic fluoride: Changes related to previous fluoride intake renal function and bone resorption. Clin Sci 58:145–152.
Watson AP, Griffin GD. 1992. Toxicity of vesicant agents scheduled for destruction by the chemical stockpile disposal program. Environ Health Perspect 98:259–280.1486858
Weast RC, Lide DR, Astle MJ, 1989. CRC handbook of chemistry and physics. 70th ed. Boca Raton, FL: CRC Press, Inc.
Weatherell JA, Strong M, Robinson C, 1986. Fluoride distribution in the mouth after fluoride rinsing. Caries Res 20:111–119.3456835
Weber CW, Reid BL. 1973. Effect of low fluoride diets fed to mice for six generations. Proceedings of the 2nd International Symposium on Trace Element Metabolism in Animals 2:707–709.
*Weddle DA, Muhler JC. 1954. The effects of inorganic salts on fluoride storage in the rat. J Nutr 54:437–444.13212480
Wei SH, Connor CW Jr. 1983. Fluoride uptake and retention in vitro following topical fluoride application. J Dent Res 62:830–832.6575025
Weiss G, ed. 1986. Hazard chemicals data book. 2nd ed. Park Ridge, NJ: Noyes Data Corporation, 16–18.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
West PW, Lyles GR, Miller JL. 1970. Spectrophotometric determination of atmospheric fluorides. Environ Sci Technol 4:487–491.
Wheeler SM, Turner AD, Brock TB, 1988. The effect of 30 mg/ L fluoride in drinking water on ewes and their lambs and current bone levels of sheep in New South Wales, Australia. Fluoride 21:60–68.
White DA. 1980. Hydrofluoric acid. J Soc Occup Med 30:12–14.7382437
White DJ, Nancollas GH. 1990. Physical and chemical considerations of the role of firmly and loosely bound fluoride in caries prevention. J Dent Res 69(special issue):587–594.2179318
Whitford GM. 1983. Fluorides: Metabolism, mechanisms of action and safety. Dent Hyg 57:16–18, 20–22, 24–29.
Whitford GM. 1989. Plasma ion concentrations associated with acute fluoride toxicity [Abstract]. J Dent Res 68:335.
*Whitford GM. 1990. The physiological and toxicological characteristics of fluoride. J Dent Res 69(Special Issue):539–549.2179312
*Whitford GM. 1994. Effects of plasma fluoride and dietary calcium concentrations on GI absorption and secretion of fluoride in the rat. Calcif Tissue Int 54:421–425.8062161
*Whitford GM. 1997. Determinants and mechanisms of enamel fluorosis. Ciba Found Symp 205:226–245.9189628
*Whitford GM. 1999. Fluoride metabolism and excretion in children. J Public Health Dent 59(4):224–228.10682327
*Whitford GM, Johnson NA. 2003. Comparison of fluoride metabolism when administered as NaF or silicofluorides to rats. J Dent Res 82 (Special Issue A):Abst 81.
*Whitford GM, Pashley DH. 1984. Fluoride absorption: The influence of gastric acidity. Calcif Tissue Int 36:302–307.6088010
Whitford GM, Taves DR. 1973. Fluoride induced diuresis: Renal-tissue solute concentrations, functional, hemodynamic, and histological correlates in the rat. Anesthesiology 39:416–427.4758350
*Whitford GM, Williams JL. 1986. Fluoride absorption: Independence from plasma fluoride levels. Proc Soc Exper Biol Med 181:550–554.3952082
Whitford GM, Allmann DW, Shahed AR. 1987a. Topical fluorides: Effects on physiologic and biochemical processes. J Dent Res 66:1072–1078.3475325
Whitford GM, Biles ED, Birdsong-Whitford NL. 1991. A comparative study of fluoride pharmacokinetics in five species. J Dent Res 70:948–951.2045573
*Whitford GM, Birdsong-Whitford NL, Finidori C. 1990. Acute oral toxicity of sodium fluoride and monofluorophosphate separately or in combination in rats. Caries Res 24:121–126.2340542
Whitford GM, Finidori C, Birdsong-Whitform NL. 1987b. Acute LD50 values of fluorine given as sodium fluoride and/or MFP in the rat. Caries Res 21:166.
*Whitford GM, Hobbs SH, Stoddard JL, 2003. Failure to find fluoride-induced learning deficits in rats. J Dent Res 82 (Special Issue A):Abst 80.
Whitford GM, Pashley DH, Reynolds KE. 1977a. Fluoride absorption from the rat urinary bladder: A pH-dependent event. Am J Physiol 232:F10–15.13661
*Whitford GM, Pashley DH, Reynolds KE. 1979a. Fluoride tissue distribution: Short-term kinetics. Am J Physiol 236:F141–148.420295
*Whitford GM, Pashley DH, Stringer GI. 1976. Fluoride renal clearance: A pH-dependent event. Am J Physiol 230:527–532.1259032
Whitford GM, Patten JR, Reynolds KE, 1977b. Blood and urinary 18F pharmacokinetics following parenteral administration in the rat. J Dent Res 56:858–861.269166
Whitford GM, Reynolds KE, Pashley DH. 1979b. Acute fluoride toxicity: Influence of metabolic alkalosis. Toxicol Appl Pharmacol 50:31–40.40325
*Whitford GM, Sampaio FC, Arneberg P, 1999a. Fingernail fluoride: A method for monitoring fluoride exposure. Caries Res 33:462–467.10529532
*Whitford GM, Thomas JE, Adair SM. 1999b. Fluoride in whole saliva, parotid ductal saliva and plasma in children. Arch Oral Biol 44:785–788.10530910
*WHO. 1973. Trace elements in nutrition: A report of a WHO expert committee. Geneva, Switzerland: World Health Organization. Technical report series no. 532.
*WHO. 1984. Fluorine and fluorides. Geneva, Switzerland: World Health Organization, Distribution and Sales Service, Environmental Health Criteria Number 36.
WHO. 1986. Diseases caused by fluorine and its toxic compounds. In: Early detection of occupational diseases. Geneva, Switzerland: World Health Organization, 91–96.
*WHO. 1994. Fluorides and oral health: Report of a WHO expert committee on oral health status and fluoride use. Geneva, Switzerland: World Health Organization.
*WHO. 2001. Guidelines for drinking-water quality. Fluoride. World Health Organization. http://www.who.int/water_sanitation_lth/GDWQ/Chemicals/fluoridefull/html. March 27, 2001.
*WHO. 2002. Fluorides. Geneva, Switzerland: World Health Organization. Environmental Health Criteria Number. 227. http://www.inchem.org/pages/ehc.html.
*Widdowson EM, Dickerson JW T. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Windholz M, ed. 1976. The Merck index. 9th ed. Rahway, NJ: Merck & Co., Inc., 211.
Windholz M, ed. 1983. The Merck index. 10th ed. Rahway, NJ: Merck & Co., Inc., 1235.
*Wing JS, Sanderson LM, Brender JD, 1991. Acute health effects in a community after a release of hydrofluoric acid. Arch Environ Health 46(3):155–160.2039270
Wiseman A. 1970. Effects of inorganic fluoride on enzymes. In: Handbook of experimental pharmacology. New York, NY: Springer-Verlag, 20(2):48–97.
*Wohlslagel LC, Dipasquale LC, Vernot EH. 1976. Toxicity of solid rocket motor exhaust: Effects of HCl, HF, and aluminum on rodents. Journal of Combustion Toxicology 3:61.
*Wolff WA, Kerr EG. 1938. The composition of human bone in chronic fluoride poisoning. Am J Med Sci 195:493–497.
*Worl RG, Van Alstine RE, Shawe DR. 1973. Fluorine. In: Brobst DA, Pratt WP, eds. United States mineral resources. Washington, DC: U.S. Department of the Interior, 223–235.
*Xu R, Xu R. 1997. Electrocardiogram analysis of patients with skeletal fluorosis. Fluoride 30(1):16–18.
*Yamamoto S, Katagiri K, Ando M. 2001. Suppression of pulmonary antibacterial defenses mechanisms and lung damage in mice exposed to fluoride aerosol. J Toxicol Environ Health 62:485–494.
*Yiamouyiannis J, Burk D. 1977. Fluoridation and cancer: Age-dependence of cancer mortality related to artificial fluoridation. Fluoride 10:102–125.
Yiamouyiannis JA. 1993. Fluoridation and cancer: The biology and epidemiology of bone and oral cancer related to fluoridation. Fluoride 26(2):83–96.
Yoshida Y, Kono K, Watanabe M, 1986. Kinetics of fluoride excretion in human saliva. In: Tsunoda H, Yu M-H, eds. Studies in Environmental Science 27:415–422.
*Yoshida Y, Toyota S, Kono K, 1978. Fluoride ion levels in the biological fluids of electronic industrial workers. Bull Osaka Med Sch 24:56–68.757135
*Young MS, Monat JP. 1982. Development of a passive dosimeter for hydrogen fluoride monitoring. Am Ind Hyg Assoc J 43:890–896.7158604
*Yuan S, Song K, Xie Q, 1994. Experimental study of inhibition on lactation due to fluorosis in rat. Environmental Sciences 2(4):179–187.
*Yunghans RS, McMullen TB. 1970. Fluoride concentrations found in NASN samples of suspended particles. Fluoride 3:143–152.
Zanfagna PE. 1976. Allergy to fluoride. Fluoride 9:36–41.
Zankel KL, McGirr R, Romm M, 1987. Measurement of ambient ground-level concentrations of hydrogen-fluoride. JAPCA--The International Journal of Air Pollution Control and Hazardous Waste Management 37:1191–1196.
*Zhao LB, Liang GH, Zhang DN, 1996. Effect of a high fluoride water supply on children’s intelligence. Fluoride 29(4):190–192.
*Zhao W, Zhu H, Yu Z, 1998. Long-term effects of various iodine and fluorine doses on the thyroid and fluorosis in mice. Endocr Regul 32:63–70.10330519
Zhao ZL, Wu MP, Gao WH. 1995. The influence of fluoride on the content of testosterone and cholesterol in rat. Fluoride 28(3):128–130.
*Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zipkin I, Leone NC. 1957. Rate of urinary fluoride output in normal adults. Am J Public Health 47:848–851.
Zipkin I, Likins RC. 1957. Absorption of various fluorine compounds from the gastrointestinal tract of the rat. Am J Physiol 191:549–550.13487778
*Zipkin I, McClure FJ. 1952. Deposition of fluorine in the bones and teeth of the growing rat. J Nutr 47:611–620.14955714
*Zipkin I, Likins RC, McClure FJ, 1956. Urinary fluoride levels associated with use of fluoridated waters. Public Health Rep 71:767–772.13350471
Zipkin I, McClure FJ, Leone KC, 1958. Fluoride deposition in human bones after prolonged ingestion of fluoride in drinking water. Public Health Rep 73:732–740.13579110
*Zipkin I, Zucas SM, Lavender DR, 1970. Fluoride and calcification of the aorta. Calcif Tiss Res 6:173–182.
*Zlotkin SH, Atkinson S, Lockitch G. 1995. Trace elements in nutrition for premature infants. Clin Perinatol 22(1):223–240.7781254
Zong-Chen L, En-Huei W. 1986. Osteoporosis - an early radiographic sign of endemic fluorosis. Skeletal Radiology 15:350–353.3738538