# 8 REGULATIONS AND ADVISORIES

No international regulations pertaining to fluorides were found. The national and state regulations and guidelines regarding fluorides, hydrogen fluoride, and fluorine in air, water, and other media are summarized in Table 8-1.

A chronic-duration oral MRL of 0.05 mg fluoride/kg/day has been derived for fluoride. This MRL is based on a NOAEL of 0.15 mg fluoride/kg/day and a LOAEL of 0.25 mg fluoride/kg/day for skeletal effects (increased fracture rate) (Li et al. 2001). The MRL was derived by dividing the NOAEL by an uncertainty factor of 3 to account for human variability.

An acute-duration inhalation MRL of 0.02 ppm fluoride has been derived for hydrogen fluoride. This MRL is based on a minimal LOAEL of 0.5 ppm for upper respiratory tract inflammation in humans exposed to hydrogen fluoride for 1 hour (Lund et al. 1997, 1999). The MRL was derived by dividing the unadjusted LOAEL by an uncertainty factor of 30 (3 for a use of a minimal LOAEL and 10 to account for human variability).

An acute-duration inhalation MRL of 0.01 ppm has been derived for fluorine. This MRL is based on a NOAEL of 10 ppm for respiratory irritation in humans exposed to fluorine for 15 minutes (Keplinger and Suissa 1968). The MRL was derived by dividing the 24-hour adjusted NOAEL of 0.1 ppm by an uncertainty factor of 10 to account for human variability.

EPA (IRIS 2003) derived an oral reference dose (RfD) of 0.06 mg/kg/day for fluorine (soluble fluoride). The RfD was based on a NOAEL of 0.06 mg/kg/day and a LOAEL of 0.12 mg/kg/day for the cosmetic effect of dental fluorosis in children (Hodge 1950). The NOAEL was divided by an uncertainty factor of 1 to derive the RfD.

Table 8-1 Regulations and Guidelines Applicable to Fluoride, Sodium Fluoride, Hydrogen Fluoride, and Fluorine

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification Fluoride and sodium fluoride | Group 3^a^ | IARC 1987
WHO | Drinking water guideline Fluoride | 1.5 mg/L | WHO 2001
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV-TWA | | ACGIH 2000
| Fluoride | 2.5 mg/m^3^
| Fluorine | 1.0 ppm
| STEL (ceiling)
| Fluorine | 2.0 ppm
| Hydrogen fluoride | 3.0 ppm
EPA | Accidental release prevention | | EPA 2001b
| Threshold quantity | | 40CFR68.130
| Fluorine | 1,000 pounds | Table 1
| Hydrogen fluoride | 1,000 pounds
| Accidental release prevention | | EPA 2001a
| Toxic end point | | 40CFR68
| Fluorine | 0.0039 mg/L | Appendix A
| Hydrogen fluoride | 0.0160 mg/L
OSHA | PEL (8-hour TWA) | | OSHA 2001c
| General industry | | 29CFR1910.1000
| Fluoride | 2.5 mg/m^3^ | Table Z-1
| Fluorine | 0.2 mg/m^3^
| Hydrogen fluoride | 2.0 mg/m^3^
| PEL (8-hour TWA) | | OSHA 2001f
| Construction industry | | 29CFR1926.55
| Fluoride | 2.5 mg/m^3^ | Appendix A
| Fluorine | 0.2 mg/m^3^
| Hydrogen fluoride | 2.0 mg/m^3^
| PEL (8-hour TWA) | | OSHA 2001a
| Shipyards | | 29CFR1915.1000
| Fluoride | 2.5 mg/m^3^ | Table Z
| Fluorine | 0.2 mg/m^3^
| Hydrogen fluoride | 2.0 mg/m^3^
| Highly hazardous chemicals | | OSHA 2001d
| Threshold quantity | | 29CFR1910.119
| Fluorine | 1,000 pounds | Appendix A
| Highly hazardous chemicals | | OSHA 2001e
| Threshold quantity | | 29CFR1926.64
| Hydrogen fluoride | 1,000 pounds | Appendix A
OSHA | Brazing and gas welding fluxes shall have a cautionary wording to indicate that they contain fluorine compounds | | OSHA 2001b; 29CFR1910.252(c)(1)
NIOSH | REL (TWA) | | NIOSH 2001a
| Fluorine | 0.2 mg/m^3^ | NIOSH 2001b
| Hydrogen fluoride | 2.5 mg/m^3^ | NIOSH 2001c
| Sodium fluoride | 2.5 mg/m^3^
| IDLH | | NIOSH 2001a
| Fluorine | 25 ppm | NIOSH 2001b
| Hydrogen fluoride | 30 ppm | NIOSH 2001c
| Sodium fluoride | 250 ppm
USC | HAP | | USC 2001
| | | 42USC7412
b. Water
EPA | BPT effluent limitation–fluoride | | EPA 2001c
| Maximum for 1 day | 6.1 kg/kkg | 40CFR415.82
| Average of daily values for 30 consecutive days | 2.9 kg/kkg
| Effluent limitation–fluoride | | EPA 2001e
| Maximum for 1 day | 75 mg/L | 40CFR422.42
| Average of daily values for 30 consecutive days | 25 mg/L
| Groundwater protection standards at inactive uranium processing sites–listed constituents include fluorine and hydrogen fluoride | | EPA 2001f; 40CFR192; Appendix I
| MCLG–fluoride | 4.0 mg/L | EPA 2001j; 40CFR141.51(b)
| MCL–fluoride | 4.0 mg/L | EPA 2001k; 40CFR141.62(b)
| Secondary MCL–fluoride | 2.0 mg/L | EPA 2001l; 40CFR143.3
| Water pollution–hazardous substance designation | Hydrogen fluoride; Sodium fluoride | EPA 2001r; 40CFR116.4
c. Food
EPA | Pesticides–fluorine compounds; residue tolerances | | EPA 2001n; 40CFR180.145
| Apricots, beets, blackberries, blueberries, boysenberries, broccoli, brussels sprouts, cabbage, cauliflower, citrus fruits, collards, cranberries | 7 ppm
EPA | Pesticides–fluorine compounds; residue tolerances | | EPA 2001n; 40CFR180.145
EPA | Cucumbers, dewberries, eggplant, grapes, kale, kohlrabi, lettuce, loganberries, melons, nectarines, peaches, peppers, plums, pumpkins, radish, raspberries, rutabaga, squash, strawberries, tomatoes, turnip, youngberries | 7 ppm
| Potatoes | 2 ppm
| Potatoes, processing waste | 22 ppm
| Kiwifruit | 15 ppm
FDA | Adhesive component, indirect food additive–for use only as bonding agent for aluminum foil, stabilizer, or preservative | Total fluoride from all sources not to exceed 1% by weight of the finished adhesive | FDA 2000e; 21CFR175.105(c)(5)
| Hydrogen fluoride
| Sodium fluoride
| Bottled water–no fluoride added | [underlined: Temperature]^b^ [underlined: mg/L] | FDA 2000g
| | 53.7-below 2.4 | 21CFR165.110
| | 53.8–58.3 2.2
| | 58.4–63.8 2.0
| | 63.9–70.6 1.8
| | 70.7–79.2 1.6
| | 79.3–90.5 1.4
| Bottled water–fluoride added | [underlined: Temperature]^b^ mg/L
| | 53.7-below 1.7
| | 53.8–58.3 1.5
| | 58.4–63.8 1.3
| | 63.9–70.6 1.2
| | 70.7–79.2 1.0
| | 79.3–90.5 0.8
| Over-the-counter drug products Labeling–fluoride, fluorine, and sodium fluoride | | FDA 2000b; 21CFR355.50
| | | FDA 2000c; 21CFR355.60
| Over-the-counter drug products Testing–fluoride | | FDA 2000d; 21CFR355.70
| Over-the-counter drug products Active ingredient–fluorine, hydrogen fluoride, and sodium fluoride | | FDA 2000a; 21CFR355.10; FDA 2000f; 21CFR310.545(a)(2)
FDA | Surface component, food contact–sodium fluoride for use as preservative only | | FDA 2000h; 21CFR177.2800 (d)(5)
d. Other
ACGIH | Carcinogenicity classification | | ACGIH 2000
| Fluoride | A4^c^
| BEI
| Fluorides in urine
| Prior to shift | 3 mg/g creatinine
| End of shift | 10 mg/g creatinine
CPSC | Requirements for child-resistant packaging for household products containing elemental fluoride | More than 50 mg and more than 0.5% | CPSC 2001; 16CFR1700
DOT | Hazardous materials | | DOT 2001
| Reportable quantity | | 40CFR172.101
| Fluorine | 10 pounds | Appendix A
| Hydrogen fluoride | 100 pounds
| Sodium fluoride | 1,000 pounds
EPA | RfD–fluorine | 6×10^−2^ mg/kg/day | IRIS 2003
| Toxic chemical release reporting; Community Right-to-Know–effective date | | EPA 2001q; 40CFR372.65
| Fluorine | 01/01/95
| Hydrogen fluoride | 01/01/87
| Contaminated soil–fluoride | Concentrations greater than 10 times UTS | EPA 2001d; 40CFR268.49(f)
| Hazardous waste–health based limits for exclusion of waste-derived-residue | | EPA 2001g; 40CFR266; Appendix VII
| Fluorine residue concentration limit | 4.0 mg/kg
| Hazardous waste–identification and listing | | EPA 2001h; 40CFR261.33(e)
| Fluorine | P056 | EPA 2001i
| Hydrogen fluoride | U134 | 40CFR261.33(f)
| Pesticides–residue tolerances | Not more than 25% of pesticide formulation | EPA 2001m
| Sodium fluoride | Not more than 25% of pesticide formulation | 40CFR180.1001(d)
| Superfund–reportable quantity | | EPA 2001o
| Fluorine | 1 pound | 40CFR302.4
| Hydrogen fluoride | 5,000 pounds | Appendix A
| Sodium fluoride | 5,000 pounds
EPA | Superfund–extremely hazardous | | EPA 2001p
| Reportable quantity | | 40CFR355
| Fluorine | 10 pounds | Appendix A
| Hydrogen fluoride | 100 pounds
| Threshold planning quantity
| Fluorine | 500 pounds
| Hydrogen fluoride | 100 pounds
[underlined: STATE]
a. Air
Connecticut | HAP–fluoride, fluorine, and hydrogen fluoride | | BNA 2001
Hawaii | Air contaminant–hydrogen fluoride | | BNA 2001
Idaho | Toxic air pollutants | | BNA 2001
| Fluoride
| OEL | 2.5 mg/m^3^
| EL | 0.167 pounds/hour
| AAC | 0.125 mg/m^3^
| Fluorine
| OEL | 2.0 mg/m^3^
| EL | 0.133 pounds/hour
| AAC | 0.1 mg/m^3^
Michigan | PEL (TWA) | | BNA 2001
| Fluoride | 2.5 mg/m^3^
| Fluorine | 0.2 mg/m^3^
| Hydrogen fluoride | 3.0 ppm
Montana | Air contaminant (TWA) | | BNA 2001
| Fluoride | 2.5 mg/m^3^
| Fluorine | 0.2 mg/m^3^
| Hydrogen fluoride | 2.0 mg/m^3^
New Mexico | Toxic air pollutant | | BNA 2001
| Fluorides
| OEL | 2.5 mg/m^3^
| Emissions | 0.167 pounds/hour
| Fluorine
| OEL | 2.0 mg/m^3^
| Emissions | 0.133 pounds/hour
New York | Air contaminant (TLV) | | BNA 2001
| Fluoride | 2.5 mg/m^3^
| Fluorine | 0.2 mg/m^3^
| Hydrogen fluoride | 2.0 mg/m^3^
Washington | Toxic air pollutant–ASIL | | BNA 2001
| Fluoride | 8.3 μg/m^3^
| Fluorine | 5.3 μg/m^3^
| Hydrogen fluoride | 8.7 μg/m^3^
| PEL | | BNA 2001
| Fluoride | 2.5 mg/m^3^
| Fluorine | 0.2 mg/m^3^
| Hydrogen fluoride (STEL) | 3.0 ppm
Wisconsin | Emission rate (pounds/hour) | [underlined: <25 feet] [underlined: >25 feet] | BNA 2001
| Fluoride | 0.2088 0.8640
| Fluorine | 0.1656 0.6720
| Hydrogen fluoride | 0.1272 0.4800
b. Water
Alaska | MCL–fluoride | 4.0 mg/L | BNA 2001
| Secondary MCL–fluoride | 2.0 mg/L
Arizona | Drinking water guideline–fluoride | 4.0 mg/L | HSDB 2003
| Reporting limit–fluoride | 2.0 mg/L | BNA 2001
California | Drinking water standards–fluoride | 2.0 mg/L | HSDB 2003
Connecticut | MCL–fluoride | 4.0 mg/L | BNA 2001
Delaware | Drinking water standards–fluoride | 1.8 mg/L | HSDB 2003
Georgia | MCL–fluoride | 4.0 mg/L | BNA 2001
Hawaii | Drinking water standards–fluoride | 1.4–2.4 mg/L | HSDB 2003
Idaho | Groundwater quality standards–fluoride | 4.0 mg/L | BNA 2001
Kansas | Agriculture–fluoride | | BNA 2001
| Livestock | 2.0 mg/L
| Irrigation | 1.0 mg/L
| Public health food–fluoride
| Domestic water supply | 2.0 mg/L
Maine | Drinking water guideline–fluoride | 2.4 mg/L | HSDB 2003
| Maximum exposure guideline | 2.4 mg/L | BNA 2001
| Action level | 1.2 mg/L
Mississippi | Groundwater standards–fluoride | 4.0 ppm | BNA 2001
Nebraska | MCL–fluoride | 4.0 mg/L | BNA 2001
New Jersey | Groundwater quality criteria–fluoride | 2.0 mg/L | BNA 2001
| PQL–fluoride | 0.5 mg/L
New York | Groundwater effluent limitations–fluoride | 3.0 mg/L | BNA 2001
| MCL–fluoride | 2.2 mg/L | BNA 2001
North Carolina | Drinking water standards–fluoride | 4.0 mg/L | HSDB 2003
North Dakota | MCL–fluoride | 4.0 mg/L | BNA 2001
Oklahoma | MCL–fluoride | 4.0 mg/L | BNA 2001
Pennsylvania | Drinking water standards–fluoride | 2.0 mg/L | HSDB 2003
Rhode Island | MCLG–fluoride | 4.0 ppm | BNA 2001
| MCL–fluoride | 4.0 ppm
South Dakota | Groundwater quality standards–fluoride | 2.4 mg/L | BNA 2001
Tennessee | MCL–fluoride | 4.0 ppm | BNA 2001
Texas | MCL–fluoride | 4.0 mg/L | BNA 2001
Utah | Groundwater standards | 4.0 mg/L | BNA 2001
| MCL–fluoride | 4.0 mg/L | BNA 2001
Vermont | Groundwater quality standards–fluoride | | BNA 2001
| Enforcement standard | 4.0 mg/L
| Preventive action level | 2.0 mg/L
| MCL–fluoride | 4.0 mg/L | BNA 2001
Washington | MCL–fluoride | 4.0 mg/L | BNA 2001
West Virginia | Groundwater standards | Not to exceed 4.0 mg/L | BNA 2001
Wisconsin | MCLG–fluoride | 4.0 mg/L | BNA 2001
| MCL–fluoride | 4.0 mg/L
| Groundwater standards–fluoride Enforcement standard | 4.0 mg/L | BNA 2001
| Preventive action limit | 0.8 mg/L
c. Food | | No data
d. Other
Connecticut | Use of pesticides; control of registrations and uses–sodium fluoride | For use as a wood preservative | BNA 2001
Minnesota | Hazardous substance–fluoride (as F, as dust), fluorides (inorganic), fluorine, and hydrogen fluorine | | BNA 2001
New Jersey | Hazardous substance–fluorine and hydrogen fluoride | | BNA 2001

a Group 3: not classifiable as to its carcinogenicity to humans

b Temperature: annual average of maximum daily air temperatures (°F)

c A4: not classifiable as a human carcinogen

AAC = acceptable ambient concentrations; ACGIH = American Conference of Governmental Industrial Hygienists; ASIL = acceptable source impact levels; BEI = biological exposure indices; BNA = Bureau of National Affairs; BPT = best practicable control technology; CFR = Code of Federal Regulations; CPSC = Consumer Product Safety Commission; DOT = Department of Transportation; EL = emissions levels; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HAP = hazardous air pollutant; HSDB = Hazardous Substances Data Bank; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life and health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; OEL = occupational exposure limit; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; PQL = practical quantitation level; REL = recommended exposure limit; RfD = reference dose; STEL = short term exposure limit; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; UTS = universal treatment standards; WHO = World Health Organization