# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTIFY

The common synonyms and other information for fluorine, hydrogen fluoride, sodium fluoride, fluorosilicic acid, and sodium fluorosilicate are listed in Table 4-1. The terms “fluorine” and “fluoride” are often used interchangeably in the literature as generic terms. In this document, we will use “fluoride” as a general term to refer to all combined forms of fluorine unless the particular compound or form is known and there is a reason for referring to it. The term “fluorine gas” will sometimes be used to emphasize the fact that we are referring to the elemental form of fluorine rather than a combined form. In general, the differentiation between different ionic and molecular or gaseous and particulate forms of fluorine-containing substances is uncertain and may also be unnecessary.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Fluorine is the lightest member of Group 17 (VIIA) of the periodic table. This group, the halogens, also includes chloride, bromine, and iodine. As with the other halogens, fluorine occurs as a diatomic molecule, F_2_, in its elemental form. It has only one stable isotope and its valence in all compounds is −1. Fluorine is the most reactive of all the elements, which may be attributed to its large electronegativity (estimated standard potential +2.85 V). It reacts at room temperature or elevated temperatures with all elements other than nitrogen, oxygen, and the lighter noble gases. Fluorine is also notable for its small size; large numbers of fluorine atoms fit around atoms of another element. This, along with its electronegativity, allows the formation of many simple and complex fluorides in which the other element is in its highest oxidation date. Important physical and chemical properties of fluorine, hydrogen fluoride, sodium fluoride, fluorosilicic acid, and sodium fluorosilicate are presented in Table 4-2. It should be noted that fluorosilicic acid only exists in aqueous solution, and not in the anhydrous state. Its properties will depend on its concentration and temperature (Aigueperse et al. 1988).

Table 4-1 Chemical Identity of Fluorine, Hydrogen Fluoride, Sodium Fluoride, Fluosilicic Acid, and Sodium Silicofluoride^a^

Characteristic | Fluorine | Hydrogen fluoride | Sodium fluoride | Fluorosilicic acid | Sodium fluorosilicate
Synonym(s)^c^ | Fluorine-19 | Hydrofluoric acid; hydrofluoride | Monosodium fluroride^b^ | Dihydrogen hexafluorosilicate; hexafluorosilicic acid; fluosilicic acid; hexafluosilicic acid; hydrofluorosilicic acid; hydrogen hexafluorosilicate; hydrosilicofluoric acid; silicofluoric acid; silicon hexafluoride dihydride | Disodium hexafluorosilicate; disodium silicofluoride; silicon sodium fluoride; sodium silicofluoride; sodium fluosilicate; sodium hexafluorosilicate; sodium hexafluosilicate; sodium silicon fluoride
Registered trade name(s)^c^ | No data | No data | Alcoa sodium fluoride^b^ | FKS | Prodan; Salufer
Chemical formula | F_2_ | FH | FNa | H_2_SiF_6_ | Na_2_SiF_6_
Chemical structure | F-F | H-F | Na-F | [image] | [image]
Identification numbers:
CAS registry | 7782-41-4 | 7664-39-3 | 7681-49-4 | 16961-83-4 | 16893-85-9
NIOSH RTECS | NIOSH/LM64750000 | NIOSH/MW7890000 | NIOSH/WB0350000 | NIOSH/VV8410000 | NIOSH/VV8225000
EPA hazardous waste | P056 | U134 | No data | No data | No data
OHM/TADS | No data | 7216750 | 7216897 | No data | No data
DOT/UN/NA/IMO shipping | UN1045; fluorine | UN1790; hydrofluoric acid solution UN1052; anhydrous hydrogen fluoride | UN1690; sodium fluoride | UN 2674; sodium silicofluoride | UN 1778; fluosilicic acid
HSDB | 541 | 546 | 1766 | 770 | 2018
EINECS | 231-954-8 | 231-634-8 | 231-667-8 | 241-034-8 | 240-934-8
NCI | No data | No data | C55221 | No data | No data

a All information obtained from HSDB 2003 and ChemID 2001 except where noted.

b Sodium fluoride is an ingredient in many dental care products and rodenticides. Since it is not the only component in these products, they cannot properly be considered trade names or synonyms. Some of these products are: Floridine, Antibulit, Cavi-trol, Chemifluor, Credo, Duraphat, F1-tabs, Florocid, Flozenges, Fluoral, Fluorident, Fluorigard, Fluorineed, Fluorinse, Fluoritab, Fluorocid, Fluor-o-kote, Fluorol, Fluoros, Flura, Flura drops, Flura-gel, Flura-Loz, Flurcare, Flursol, Fungol B, Gel II, Gelution, Gleem, Iradicav, Karidium, Karigel, Kari-rinse, Lea-Cov, Lemoflur, Luride, Luride Lozi-tabs, Luride-SF, Nafeen, Nafpak, Na Frinse, Nufluor, Ossalin, Ossin, Osteofluor, Pediaflor, Pedident, Pennwhite, Pergantene, Phos-flur, Point Two, Predent, Rafluor, Rescue Squad, Roach salt, So-flo, Stay-flo, Studafluor, Super-dent, T-fluoride, Thera-flur, Thera-Flur-N, Villiaumite, and Zymafluor. Another compound of sodium and fluorine is sodium bifluoride (also called sodium hydrofluoride and sodium hydrofluoride), NaF-HF or NaHF2, which is not discussed here.

c IARC 1982

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Organization Code; EINECS = European INventory of Existing Chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Fluorine, Hydrogen Fluoride, Sodium Fluoride, Fluosilicic Acid, and Sodium Silicofluoride^a^

Property | Fluorine | Hydrogen fluoride | Sodium fluoride | Fluorosilicic Acid | Sodium Fluorosilicate
Molecular weight | 37.997 | 20.006 | 42.00 | 144.1 | 188.1
Color | Pale yellow | Colorless | Colorless | Colorless, fuming liquid | white
Physical state | Gas | Gas | Cubic or tetragonal crystals | liquid | granular powder
Molecular formula | F_2_ | FH | FNa | H_2_SiF_6_ | Na_2_SiF_6_
Melting point, °C | −219.61 | −83.36 | 993 | 60–70% solution solidifies at about 19 °C, forming a crystalline dihydrate | decomposes at red heat^b^
Boiling point, °C | −188.13 | 19.51b | 1,704 | decomposes | decomposes at red heat^b^
Density, g/cm^3^ | 1.5127 at −188.13 °C | 0.991 at 19.54 °C | 2.78 | 1.4634 (60.97% solution) at 25 °C: 17.5/17.5 1.2742 (30% solution)^f^ | 2.679^f^
Odor | Pungent, irritating odor | Strong, irritating odor | Odorless | Sour, pungent odor^b^ | No data
Odor threshold:
Water | Not relevant | No data | No data | No data | No data
Air | 0.035 ppm | 0.5–3 ppm | No data | No data | No data
Solubility:
Water | 1.69 mg/L | Miscible | 43 g/L at 25 °C | No data | 0.76 g/100 g water at 25 °C^g^
Organic solvents | No data | Benzene (2.54); toluene (1.80); ethanol (very soluble); m-xylene (1.28); tetraline (0.27)^b^ | Very slightly soluble in ethanol | No data | No data
Partition coefficients:
Log K_ow_ | Not relevant | No data | No data | No data | No data
Log K_oc_ | Not relevant | Not relevant | No data | No data | No data
Vapor pressure | 0.4 kPa (3 mmHg) at 55 °K^c^; 12.3 kPa (92.3 mmHg) at 70 °K | 400 mmHg at 2.5 °C | 1 mmHg at 1,077 °C | No data | No data
Henry’s Law constant at 20 °C | No data | 0.104 at m-L/mole^e^ | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data
Flashpoint | Not flammable | Not flammable | Not flammable | No data | No data
Flammability limits | No data | No data | No data | No data | No data
Conversion factors | 1 mg/m^3^ = 1.554 ppm^d^; 1 ppm = 0.64 mg/m^3^ | 1 mg/m^3^ = 1.223 ppmd; 1 ppm = 0.82 mg/m^3^ | Not applicable | Not applicable | Not applicable
Explosive limits | No data | No data | No data | No data | No data

a All information obtained from HSDB 2003 except where noted

b Budavari 2001

c Lide 1992

d NAS 1971a

e Betterton 1992; apparent Henry’s law constant (ratio of the gas phase concentration to that of the total dissolved solute)

f IARC 1982

g Aigueperse et al. 1988