# APPENDIX D FLUORIDE AND DENTAL CARIES

Dental caries or tooth decay is a progressively destructive disease of the tooth caused by cariogenic bacteria. These bacteria, which reside in dental plaque, colonize on tooth surfaces and produce polysaccharides that enhance adherence of the plaque to the tooth enamel. Once plaque is formed, the bacteria on the teeth produce an enzyme that promotes erosion of the enamel by converting sugars and other fermentable carbohydrates into acids. The acids dissolve the minerals (calcium and phosphorus) in the tooth enamel in a process known as demineralization (DHHS 2001b).

Several studies conducted by Dean and associates in the 1930s and 1940s demonstrated a relationship between the levels of naturally-occurring fluoride in drinking water and the prevalence of dental caries (Dean 1938; Dean et al. 1939, 1941, 1942). Children living in communities with high levels of fluoride in the drinking water had lower occurrences of dental caries. This relationship between fluoride and dental caries prompted the city of Grand Rapids, Michigan to implement a water fluoridation program in 1945. Studies conducted in some of the earliest cities to adopt a fluoridation program reported dramatic decreases in the occurrence of dental caries (Ast et al. 1951; Dean et al. 1950; Hill et al. 1951; Hutton et al. 1951). The prevalence of dental caries in children living in communities with fluoridated water was 50–70% lower than in children living in areas without fluoridated water. Surveys conducted after the late 1980s found smaller differences; the occurrence of dental caries was 9–25% lower in communities with fluoridated water as compared to communities without fluoridated water (Brunelle and Carlos 1990; DeLiefde 1998; Eklund et al. 1987; Englander and DePaola 1979; Jackson et al. 1995; Selwitz et al. 1995). In one study, no significant differences in the occurrence of dental caries was found in school-aged children 5–17 years old (Yiamouyiannis 1990); however, when just 5 year olds were examined, the incidence of dental caries was 42% lower in children with lifetime exposure to fluoridated water and 24% lower in children exposed to fluoridated water for only a portion of their lifetime. Several studies have also examined the impact of termination of a water fluoridation program on the incidence of dental caries. Conflicting results have been reported. Some studies found increases in dental caries occurrence (Attwood and Blinkhorn 1991; Stephen et al. 1987; Thomas et al. 1995), some found no change in the occurrence of dental caries (Burt et al. 2000; Kalsbeek et al. 1993; Künzel and Fischer 1997; Seppä et al. 2000; Stephen et al. 1987), and other studies found decreases in dental caries occurrence (Künzel and Fischer 2000; Künzel et al. 2000; Maupomé et al. 2001). A meta-analysis of 26 studies examined the relationship between water fluoridation and prevalence of dental caries or the change in decayed, missing, and filled teeth (DMFT) (McDonagh et al. 2000). In 19 of the 30 analyses conducted, a significant increase in the prevalence of children without dental caries was found in the fluoridated areas compared to non-fluoridated areas. Additionally, 15 of the 16 analyses found a significant increase in the mean change in DMFT in fluoridated water areas (levels of DMFT declined in response to fluoridation).

The decline or stabilization of the occurrence of dental caries in the absence of water fluoridation has been attributed to a number of factors (Horowitz 1996), including diffusion of effects of fluoridated drinking water, dilution effects from other sources of fluoride on the measurement of effectiveness of community water fluoridation, and improved dental care. The diffusion effect occurs when residents of communities without fluoridated water consume products manufactured or bottled in areas with fluoridated water (thus fluoride enters the foodstuff) or attend schools in areas with fluoridated water. An often cited example of the diffusion effect is the 1986–1987 NIDR survey of dental health status of U.S. school children (Brunelle and Carlos 1990). In the Pacific region, which has a low percentage of communities with fluoridated water (19%), children living in area with nonfluoridated water have 61% higher dental caries score as compared to children living in areas with fluoridated water. In contrast, in the Midwest region with a high percentage of communities with fluoridated water (74%), there is no difference in dental caries scores between fluoridated and nonfluoridated areas. The dilution effect is due to the development and use of other fluoride agents, including fluoride supplements, fluoride solutions, gels, and varnishes used by dental professionals, fluoridated toothpaste, and fluoride mouthwash. The use of the fluoride products that provide protection from dental decay diminishes the difference in the levels of dental decay between fluoridated and nonfluoridated communities (Ripa 1993).

The primary mechanism by which fluoride prevents the occurrence of dental caries is through its influence on the demineralization and remineralization process (Featherstone 1999; Koulourides 1990; Ten Cate 1999). The acid produced from the metabolism of sugars and fermentable carbohydrates by cariogenic bacteria in plaque begins to dissolve or demineralize the enamel crystal surface of the tooth resulting in the loss of calcium, phosphate, and carbonate from the tooth enamel. The increased acid production results in a decrease in plaque pH and the release of fluoride from the dental plaque. This fluoride, along with calcium and phosphate, is incorporated into the apatite molecule to form fluor(hydroxyl)apatite. In the presence of fluoride, cycles of partial demineralization and then remineralization will create apatite, which has less carbonate, more fluoride, and is less soluble. Fluor(hydroxyl)apatite, which has high levels of fluoride and low levels of carbonate, is more acid resistant (Chow 1990; Ericsson 1977; Featherstone 1999; Kidd et al. 1980; Ten Cate 1999; Thylstrup 1990; Thylstrup et al. 1979). When the beneficial effects of fluoride on caries prevention was first discovered, it was believed that the incorporation of the fluoride into developing enamel resulted in improved enamel and dental caries prevention (Dean et al. 1935; McClure and Likins 1951). However, more recent data suggest that fluoride works primarily after teeth have erupted (Clarkson et al. 1996). In a fluoride-rich environment, demineralization and remineralization cycling, which occurs throughout the lifetime of the tooth, will result in teeth that are more resistant to cariogenic bacterial damage. Another mechanism in which fluoride prevents dental caries is via a direct effect on cariogenic bacterial metabolism. There are in vitro data that demonstrate that fluoride can inhibit bacterial metabolism of carbohydrates, which results in a decreased production of acids (Bowden 1990; Bowden et al. 1982; Marquis 1990; Rosen et al. 1978). However, it is likely that this would occur at fluoride levels that far exceed those present in the mouth (Geddes and Bowen 1990).

Based on this relationship between fluoride and dental caries prevention, the Institute of Medicine (IOM 1997) and the World Health Organization (WHO 2002) consider fluoride to be an essential dietary element. The Institute of Medicine has derived adequate intake levels (AIs) ranging from 0.01 to 4 mg/day (IOM 1997). The AIs for each age group are presented below:

Age Range | Adequate Intake Level (mg/day)
0–6 months | 0.01
6–12 months | 0.5
1–3 years | 0.7
4–8 years | 1
9–13 years (males and females) | 2
14–18 years (males and females) | 3
>18 years (males) | 4
>18 years (females) | 3

Expert panels convened by the U.S. Department of Health and Human Services (DHHS 1991, 2000, 2001b) and the World Health Organization (WHO 1994) support optimal fluoridation of drinking water. A work group assembled by the Centers for Disease Control and Prevention (DHHS 2001b) made the following recommendation:

“Because frequent exposure to small amounts of fluoride each day will best reduce the risk for dental caries in all age groups, the work group recommends that all persons drink water with an optimal fluoride concentration and brush their teeth twice daily with fluoride toothpaste. For persons at high risk of dental caries, additional fluoride measures might be needed. Measured use of fluoride modalities is particularly appropriate during the time of anterior tooth enamel development (i.e., age <6 years).”