# APPENDIX A ATSDR MINIMAL RISK LEVEL AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agencywide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road, Mailstop E-29, Atlanta, Georgia 30333.

## Fluoride Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Fluoride
CAS Number: | NA
Date: | December 1, 2003
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Key to Figure: | 53
Species: | Humans

[underlined: Minimal Risk Level]: 0.05 [X] mg/kg/day [ ] mg/m^3^

[underlined: Reference]: Li Y, Liang C, Slemenda CW, 2001. Effect of long-term exposure to fluoride in drinking water on risks of bone fractures. J Bone Miner Res 16:932–939.11341339

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Six communities in rural China with different levels of naturally occurring fluoride in the water were examined. The subjects were 50 years and older; the mean ages ranged from 62.6 to 64.0 years. The majority of the subjects had been living in the same community since birth. There was a higher percentage of males in the highest fluoride group (52.4%) than in the other groups (41.8–47.0%). The water fluoride concentrations were 0.25–0.34, 0.58–0.73, 1.00–1.06, 1.45–2.19, 2.62–3.56, and 4.32–7.97 ppm. Three-day dietary surveys were collected for 10% of randomly selected subjects; estimated nutrition levels were adequate for all six populations. None of the subjects used fluoride-containing toothpaste or mouthwashes and there was a minimal use of packaged beverages and canned foods; fluoride levels in brewed tea samples were largely determined by the levels of fluoride in the water. The authors calculated total daily fluoride intakes of 0.7, 2, 3, 7, 8, and 14 mg/day. The subjects self-reported bone fractures. If the fracture received medical attention, then original x-rays were obtained; for other fractures, x-rays were taken to verify self-reported fractures. The reliability of the reported fracture was 99.1%.

[underlined: Effects noted in study and corresponding concentrations]: Age, gender, alcohol consumption, and level of physical activity were significant factors for the risk of overall bone fractures since age 20 years; cigarette smoking and BMI did not significantly alter bone fracture prevalence. The trend for overall bone fracture prevalence (adjusted for age and gender) had a U-shaped pattern. As compared to the 1.00–1.06 ppm group, significantly higher prevalences of bone fracture were found in the lowest (0.25–0.34 ppm fluoride) and highest (4.32–7.97 ppm) groups. The prevalences were 7.41, 6.40, 5.11, 6.04, 6.09, and 7.40%, respectively. When only hip fractures since age 20 were examined, significantly higher prevalences (adjusted for age and BMI) were found in the highest fluoride group, as compared to the 1.00–1.06 ppm group. The prevalences of hip fractures were 0.37, 0.43, 0.37, 0.89, 0.76, and 1.20%, respectively. A similar pattern was observed when overall fractures since age 50 were examined; the prevalences were 4.33, 3.20, 3.28, 3.30, 3.62, and 4.80 (p=0.02), respectively. Only a small number of subjects reported spine fractures (49); none of the fluoride groups significantly differed from the 1.00–1.06 ppm group.

[underlined: Concentration and end point used for MRL derivation]:

The MRL is based on a NOAEL of 0.15 mg fluoride/kg/day for increased fracture rate.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL in a sensitive subpopulation
- [ ] 10 for extrapolation from animals to humans
- [X] 3 for human variability; a value less than 10 was used because the most sensitive population, elderly men and women, were examined.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] Yes. Doses were calculated using the reported daily fluoride intakes of 0.7, 2, 3, 7, 8, and 14 mg/day and a reference body weight of 55 kg.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration]: NA

[underlined: Was a conversion used from intermittent to continuous exposure?] NA

[underlined: Other additional studies or pertinent information that lend support to this MRL:] A number of studies have examined the possible association between exposure to fluoridated water and the risk of increased bone fractures, in particular, hip fractures. In general, the studies involved comparing the incidence of hip fractures among residents aged 55 years and older living in a community with fluoridated water (around 1 ppm) with the incidence in a comparable community with low levels of fluoride in the water. Inconsistent results have been found, with studies finding decreases (Lehmann et al. 1998; Phipps et al. 2000; Simonen and Laittinen 1985), increases (Cooper et al. 1990, 1991; Danielson et al. 1992; Jacobsen et al. 1990, 1992; Kurttio et al. 1999), or no effect (Arnala et al. 1986; Cauley et al. 1995; Goggin et al. 1965; Jacobsen et al. 1993; Karagas et al. 1996; Kröger et al 1994; Suarez-Almazor et al. 1993) on hip fracture risk. Studies by Li et al. (2001) and Sowers et al. (1986) have examined communities with higher levels of naturally occurring fluoride in the water. Both studies found increases in the incidence of hip fractures in residents exposed to 4 ppm fluoride and higher (Li et al. 2001; Sowers et al. 1986, 1991); the hip fracture incidence in the highly exposed community was compared to the rates in communities with approximately 1 ppm fluoride in the water. Significant increases in the occurrence of nonvertebral fractures were also observed in postmenopausal women ingesting sodium fluoride (34 mg fluoride/kg/day) for the treatment of osteoporosis (Riggs et al. 1990, 1994). This result was not found in another study of postmenopausal women with spinal osteoporosis treated with 34 mg fluoride/kg/day as sodium fluoride (Kleerekoper et al. 1991). A meta-analysis of these data, as well as other clinical studies, found a significant correlation between exposure to high levels of fluoride and an increased relative risk of nonvertebral fractures (Haguenauer et al. 2000).

[underlined: Agency Contact (Chemical Manager):] Carolyn A. Tylenda, D.M.D., Ph.D., Dennis Jones, D.V.M..

## Hydrogen Fluoride Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Hydrogen Fluoride
CAS Number: | 7664-39-3
Date: | December 1, 2003
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to Figure: | 6
Species: | Humans

[underlined: Minimal Risk Level]: 0.02 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Lund K, Ekstrand J, Poe J, 1997. Exposure to hydrogen fluoride: an experimental study in humans of concentrations of fluoride in plasma, symptoms, and lung function. Occup Environ Med 54:32–37.9072031

Lund K, Refsnes M, Sandstrøm T, 1999. Increased CD3 positive cells in bronchoalveolar lavage fluid after hydrogen fluoride inhalation. Scand J Work Environ Health 25:326–334.10505658

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Groups of 7–9 healthy, nonsmoking males (21–44 years of age) were exposed to 0.2–0.6, 0.7–2.4, or 2.5–5.2 mg/m^3^ hydrogen fluoride for 1 hour. For the last 15 minutes of the exposure, the subjects performed an ergometric test at a fixed work load of 75W. Bronchoalveolar lavage (BAL) was performed 3 weeks prior to exposure and 24 hours after exposure. Lung function tests were performed immediately before exposure, every 15 minutes during exposure, at exposure termination, 30 minutes after exposure, and 1, 2, 3, and 4 hours after exposure. Symptom surveys were completed before exposure initiation, after 30 minutes of exposure, at exposure termination, and 4 and 24 hours after exposure. Eye, upper airway (nose and throat), and lower airway symptoms were scored based on a 5 point scale with 5 being the most severe.

The midpoint of the range of concentrations was used to calculate ppm levels: 0.4 mg hydrogen fluoride/m^3^ × 24.45/20 × 19/20 = 0.5 ppm fluoride; 1.7 mg/m^3^ = 1.9 ppm, 3.9 mg/m^3^ = 4.5 ppm

[underlined: Effects noted in study and corresponding concentrations]: No significant exposure-related alterations in lung function (FEV1 or FVC) were observed and no significant correlations between plasma fluoride concentrations and FVC or FEV1 were found. Increases (as compared to scores prior to exposure) in upper airway symptom scores were observed in the low (p=0.06) and high (p=0.02) concentration groups and for all concentrations combined (p<0.001); similarly, total symptom scores were significantly (p<0.04) increased in the low and high concentration groups and all groups combined. The severity of the upper airway score was low (scores of 1–3) in the low exposure group. All subjects reported a change in the upper airway symptom score in the high concentration group; four subjects scored the symptoms as low and three scored them as high. A significant increase in eye symptom score was also observed in all groups combined, but not for individual exposure level groups. The effect of hydrogen fluoride exposure was assessed by comparing the before and after exposure BAL fluid. Significant increases in the percentage of CD3-positive cells were found in the bronchial portion of the mid- and high-dose group and in the bronchoalveolar portion of the high-dose group. A significant increase in the percentage of lymphocytes in the bronchial and bronchoalveolar portions in the mid-concentration group was observed. A significant correlation between the individual changes in the percentage of CD3-positive cells and the changes in the percentage of lymphocytes from the bronchoalveolar portion was also observed. Significant increases in myeloperoxidase and interkeukin-6 levels were found in the high dose group.

[underlined: Concentration and end point used for MRL derivation]: The MRL is based on a minimal LOAEL of 0.5 ppm fluoride as hydrogen fluoride for upper respiratory tract irritation.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [ ] 3 for extrapolation from animals to humans with dosimetric adjustments
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration]:

[underlined: Was a conversion used from intermittent to continuous exposure?] No. Data on nasal irritation from the Largent (1960) report, the Lund et al. (2002) study, and the intermediate-duration study by Largent (1960) provide suggestive evidence that the severity of nasal irritation does not increase with increasing exposure duration. These three studies identified similar LOAEL values for different exposure durations: 3.22 ppm 6 hours/day for 10 days (Largent 1960), 3.8 ppm 1 hour/day for 1 day (Lund et al. 2002), and 2.98 ppm 6 hours/day, 6 days/week for 15–50 days. Thus, time scaling was not used to derive the acute MRL.

[underlined: Other additional studies or pertinent information that lend support to this MRL:] The respiratory tract appears to be the primary target of hydrogen fluoride toxicity. Upper respiratory tract irritation and inflammation and lower respiratory tract inflammation have been observed in several human studies. Nasal irritation was reported by one subject exposed to 3.22 ppm fluoride as hydrogen fluoride 6 hours/day for 10 days (Largent 1960). Very mild to moderate upper respiratory symptoms were reported by healthy men exposed to 0.5 ppm fluoride as hydrogen fluoride for 1 hour (Lund et al. 1997). At higher concentrations, 4.2–4.5 ppm fluoride as hydrogen fluoride for 1 hour, more severe symptoms of upper respiratory irritation were noted (Lund et al. 1997, 2002). In subjects exposed to 4.2 ppm for 1 hour, analysis of nasal lavage fluid provided suggestive evidence that hydrogen fluoride induces an inflammatory response in the nasal cavity (Lund et al. 2002). Similarly, bronchoalveolar lavage fluid analysis revealed suggestive evidence of bronchial inflammation in another study of subjects exposed to 1.9 ppm fluoride as hydrogen fluoride for 1 hour (Lund et al. 1999); no alterations were observed at 0.5 ppm. Respiratory effects have also been reported in rats acutely exposed to hydrogen fluoride. Mild nasal irritation was observed during 60-minute exposure to 120 ppm fluoride (Rosenholtz et al. 1963), and respiratory distress was observed at 2,310, 1,339, 1,308, and 465 ppm fluoride for 5, 15, 30, or 60 minutes, respectively (Rosenholtz et al. 1963). Midtracheal necrosis was reported in rats exposed to 902 or 1,509 ppm fluoride as hydrogen fluoride for 2 or 10 minutes using a mouth breathing model with a tracheal cannula (Dalbey et al. 1998a, 1998b). These effects were not observed when the tracheal cannula was not used.

The Lund et al. (1997, 1999) study was selected as the basis of the acute-duration inhalation MRL for hydrogen fluoride. As reported in the 1997 publication, a trend (p=0.06) toward increased upper respiratory tract symptom score, as compared to pre-exposure symptom scores, was observed at the lowest concentration tested (0.5 ppm). A significant increase in the total symptom score was also observed at this concentration. No significant alterations in symptom scores were observed at the mid concentration (1.9 ppm), and increases in upper respiratory and total symptom scores were observed at the high concentration (4.5 ppm). Suggestive evidence of bronchial inflammation was also observed at ≥1.9 ppm fluoride (Lund et al. 1999), although no alterations in lower respiratory tract symptoms (Lund et al. 1997) or lung function (Lund et al. 1997) were observed at any of the tested concentrations.

[underlined: Agency Contact (Chemical Manager):] Carolyn A. Tylenda, D.M.D., Ph.D., Dennis Jones, D.V.M.

## Fluorine Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Fluorine
CAS Number: | 7782-41-4
Date: | December 1, 2003
Profile Status: | Final
Route: | [X] Inhalation [ ] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Key to Figure: | 6
Species: | Humans

[underlined: Minimal Risk Level]: 0.01 [ ] mg/kg/day [X] ppm

[underlined: Reference]: Keplinger ML, Suissa LW. 1968. Toxicity of fluorine short-term inhalation. Am Ind Hyg Assoc J 29(1):10–18.5667185

[underlined: Experimental design] (human study details or strain, number of animals per exposure/control groups, sex, dose administration details): Five volunteers (aged 19–50 years; gender not specified) were exposed to various concentrations of fluorine: 10 ppm for 3, 5, or 15 minutes; 23 ppm for 5 minutes, 50 ppm for 3 minutes, 67 ppm for 1 minute, 78 ppm for 1 minute, and 100 ppm for 0.5 or 1 minute. The fluorine was administered via a mask that covered the eyes and nose; the subjects could remove the mask from their face and could breathe fresh air via their mouth. No information was provided on the amount of time between exposures or whether all subjects were exposed to all concentrations.

[underlined: Effects noted in study and corresponding concentrations]: No nasal or eye irritation was noted by subjects exposed to 10 ppm for 3, 5, or 15 minutes; it was also noted that the 15-minute exposure did not result in respiratory tract irritation. Eye irritation was observed at ≥23 ppm; nose irritation at ≥50 ppm, and skin irritation at ≥78 ppm. The severity of the irritation was concentration related. Exposure to 100 ppm was considered very irritating and the subjects did not inhale during the exposure period. No incidence data were reported.

[underlined: Concentration and end point used for MRL derivation]: The MRL is based on a NOAEL of 10 ppm and LOAEL of 23 ppm fluorine for irritation in humans.

[X] NOAEL [] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose?] No

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent concentration:] NA

[underlined: Was a conversion used from intermittent to continuous exposure?] Yes. The 15-minute exposure duration was adjusted for a continuous 24-hour exposure using the following equation:

10 ppm × 0.25 hours / 24 hours = 0.1 ppm

The study authors noted that exposure to 10 ppm for 3–5 minutes every 15 minutes over a 2- or 3-day period resulted slight irritation to the eyes and skin, but no other subjective effects (no additional details on this study were provided). These data are suggestive that the toxicity of fluorine may be dependent on concentration and duration of exposure. Thus, it is appropriate to adjust for continuous exposure.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Respiratory effects have also been observed in, rats, mice, guinea pigs, rabbits, and dogs exposed to fluorine for 1–60 minutes (Keplinger and Suissa 1968). The observed effects include diffuse lung congestion, dyspnea, irritation, and alveolar necrosis and hemorrhage. The severity of the lung congestion was concentration-related and no species differences were found.

[underlined: Agency Contact (Chemical Manager):] Carolyn A. Tylenda, D.M.D., Ph.D., Dennis Jones, D.V.M.