# 5 List of References

*Cited in text

*Allemand H, Pessayre D, Descatoire V, . 1978. Metabolic activation of trichloroethylene into a chemically reactive metabolite toxic to the liver. J Pharmacol Exp Ther 204(3):714–723.633075
*Altmann L, Wiegand H, Bottger A, . 1992. Neurobehavioral and neurophysiological outcomes of acute repeated perchloroethylene exposure. Applied Psychology: An International Review 41(3):269–279.
*Aoki N, Soma K, Katagiri H, . 1997. The pulmonary hemodynamic effects of 1,1,1-trichloroethane inhalation. Industrial Health 35:451–455.9348715
*Arito H, Takahashi M, Ishikawa T. 1994. Effect of subchronic inhalation exposure to low-level trichloroethylene on heart rate and wakefulness-sleep in freely moving rats. Sangyo Igaku 36:1–8.8126932
*Astrand I, Kilbom A, Wahlberg I, . 1973. Methylchloroform exposure: I. Concentration in alveolar air and blood at rest and during exercise. Work Environ Health 10:69–81.
*ATSDR. 1990. Toxicological profile for 1,1-dichloroethane. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services.
*ATSDR. 1992. Public health assessment guidance manual. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1995. Toxicological profile for1,1,1-trichloroethane. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services.
*ATSDR. 1997a. Toxicological profile for trichloroethylene. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services.
*ATSDR. 1997b. Toxicological profile for tetrachloroethylene. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services.
*ATSDR. 2001a. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services.
*ATSDR. 2001b. Guidance for the preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services.
*Balster RL. 1998. Neural basis of inhalant abuse. Drug and Alcohol Dependence 51:207–214.9716942
*Barton HA, Clewell HJ. 2000. Evaluating noncancer effects of trichloroethylene: Dosimetry, mode of action, and risk assessment. Environ Health Perspec 108:323–334.
*Barton HA, Creech JR, Godin CS, . 1995. Chloroethylene mixtures: Pharmacokinetic modeling and in Vitro metabolism of vinyl chloride, trichloroethylene, and trans-1,2-dichloroethylene in rat. Toxicol Appl Pharmacol 130:237–247.7871537
Bove FJ, Fulcomer MC, Klotz JB, . 1995. Public drinking water contamination and birth outcomes. Am J Epidemiol 141(9):850–862.7717362
Brown R, Blancato JN, Young D. 1997. Pharmacokinetic interactions of drinking water contaminants. In: Wang RGM, ed. Water Contamination and Health. New York: Marcel Dekker,Inc, 241–279.
*Bruckner JV, Kyle GM, Luthra R, . 2000. Acute, subacute and subchronic oral toxicity of 1,1,1-trichloroethane in rats. Toxicol Sci [in press].
*Buben JA, O’Flaherty EJ. 1985. Delineation of the role of metabolism in the hepatotoxicity of trichloroethylene and perchloroethylene: A dose-effect study. Toxicol Appl Pharmacol 78:105–122.2994252
*Bull RJ. 2000. Mode of action of liver tumor induction by trichloroethylene and its metabolites, trichloroacetate and dichloroacetate. Environ Health Perspec 108:241–259.
Cantor KP. 1997. Drinking water and cancer. Cancer Causes Control 8:292–308.9498894
*Carlson GP. 1973. Effect of phenobarbital and 3-methylcholanthrene pretreatment on the hepatoxicity of 1,1,1-trichloroethane and 1,1,2-trichloroethane. Life Sci 13:67–73.4356632
*Carlson GP. 1974. Enhancement of the hepatoxicity of trichloroethylene by inducers of drug metabolism. Res Commun Chem Pathol Pharmacol 7(3):637–640.4363358
Carlson GP. 1981. Effect of alterations in drug metabolism on epinephrine-induced cardiac arrhythmias in rabbits exposed to methylchloroform. Toxicol Lett 9:307–313.7330895
Cassee FR, Groten JP, vanBladeren PJ, . 1998. Toxicological evaluation and risk assessment of chemical mixtures. Crit Rev Toxicol 28(1):73–101.9493762
Chapin RE. 1997. Chemical mixture. Environ Health Perspect 105(Suppl. 1):371–372.
Chapin RE, Phelps JL, Schwetz BA, . 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants III Male reproduction study in B6C3F mice. Fundam Appl Toxicol 13:388–398.2612772
Clegg ED, Cook JC, Chapin RE, . 1997. Leydig cell hyperplasia and adenoma formation: mechanisms and relevance to humans. Reprod Toxicol 11(1):107–121.9138629
*Clewell HJ, Gentry PR, Covington TR, . 2000. Development of a physiologically based pharmacokinetic model of trichloroethylene and its metabolites for use in risk assessment. Environ Health Perspec 108:283–305.
*Colacci A, Arfellini G, Mazzullo M, . 1985. Genotoxicity of 1,1-dichloroethane. Res Commun Chem Pathol Pharmacol 49(2):243–254.2414829
*Cornish HH, Adefuin J. 1966. Ethanol potentiation of halogenated aliphatic solvent toxicity. Am Ind Hyg Assoc J 27:57–61.5920489
*Cornish HH, Ling BP, Barth ML. 1973. Phenobarbital and organic solvent toxicity. Am Ind Hyg Assoc J :487–492.4770171
Crebelli R, Andreoli C, Carere A, . 1995. Toxicology of halogenated aliphatic hydrocarbons: structural and molecular determinants for the disturbance of chromosome segregation and the induction of lipid peroxidation. Chem Biol Interact 98:113–129.8548852
*Cruz SL, Mirshahi T, Thomas B, . 1998. Effects of the abused solvent toluene on recombinant N-methyl-D-aspartate and non-N-methyl-D-aspartate receptors expressed in Xenopus Oocytes. J Pharmacol Exper Therap 286:334–340.9655877
Dahlstrom-King L, Couture J, Lamoureux C, . 1990. Dose-dependent cytotoxicity of chlorinated hydrocarbons in isolated rat hepatocytes. Fundam Appl Toxicol 14:833–841.2361581
Dekant W, Martens G, Vamvakas S, . 1987. Bioactivation of glutathione S-transferase-catalyzed conjugation versus cytochrome P-450-dependent phospholipid alkylation. Drug Metab Dispos 15(5):702–709.2891489
*Dallas CE, Chen XM, Muralidhara S, . 1995. Physiologically based pharmacokinetic model useful in prediction of the influence of species, dose, and exposure route on perchloroethylene pharmacokinetics. J Toxicol Environ Health 44:301–317. (As cited in ATSDR 1997b).7897693
*Dallas CE, Chen XM, Muralidhara S, . 1994a. Use of tissue disposition data from rats and dogs to determine species differences in input parameters for physiological model for perchloroethylene. Environ Res 67:54–67. (As cited in ATSDR 1997b).7925194
*Dallas CE, Muralidhara S, Chen XM, . 1994b. Use of a physiologically based model to predict systemic uptake and respiratory elimination of perchloroethylene. Tox Appl Pharm 128:60–68. (As cited in ATSDR 1997b).
*Dallas CE, Ramanathan R, Muralidhara S, . 1989. The uptake and elimination of 1,1,1-trichloroethane during and following inhalation exposures in rats. Toxicol Appl Pharmacol 98:385–397.2718170
*Dow Chemical. 1993. Examination of rats for developmental neurotoxicological effects from maternal exposure to 1,1,1-trichloroethane. (As cited in ATSDR 1995).
*D’Souza RW, Bruckner JV, Feldman S. 1985. Oral and intravenous trichloroethylene pharmacokinetics in the rat. J Toxicol Environ Health 15:587–601.4046066
*Durk H, Poyer JL, Klessen C, . 1992. Acetylene: A mammalian metabolite of 1,1,1-trichloroethane. Biochem J 286: 353–356.1326938
Durkin P. 1995. Development of mixtures assessment methods: Guidelines for application of the binary weight-of-evidence methodology. Submitted to The Kevric Company, Inc., Silver Spring, MD. SERA TR 95-018-001a.
*Engelke M, Tahti H, Vaalavirta L. 1996. Perturbation of artificial and biological membranes by organic compounds of aliphatic, alicyclic and aromatic structure. Toxicol in Vitro 10:111–115.20650189
*Evans EB, Balster RL. 1991. CNS depressant effects of volatile organic solvents. Neurosci Biobehav Rev 15:233–241. (As cited in ATSDR 1995).1852314
*Ferroni C, Selis L, Muti A, . 1992. Neurobehavioral and neuroendocrine effects of occupational exposure to perchloroethylene. Neurotoxicol 13:243–263.
*Fisher JW. 2000. Physiologically based pharmacokinetic models for trichloroethylene and its oxidative metabolites. Environ Health Perspec 108:265–273.
*Franchini I, Cavotorta A, Falzoi M, . 1983. Early indicators of renal damage in workers exposed to organic solvents. Int Arch Occup Environ Health 52:1–9.6603422
*Franks NP, Lieb WR. 1985. Mapping of general anaesthetic target sites provides a molecular basis for cutoff effects. Nature 316:349–351.4022125
*Franks NP, Lieb WR. 1987. Anaesthetics on the mind. Nature 328:113–114.3600786
*Fredriksson A, Danielsson BRG, Eriksson P. 1993. Altered behavior in adult mice orally exposed to tri- and tetrachloroethylene as neonates. Toxicol Lett 66:13–19.8427017
*Fuller GC, Olshan A, Puri SK, . 1970. Induction of hepatic drug metabolism in rats by methylchloroform inhalation. J Pharmacol Exp Ther 175(2):311–317.4394799
*Gamberale F, Hultengren M. 1973. Methylchloroform exposure. II. Psychophysiological functions. Work Environ Health 10:82–92.
Germolec DR, Yang RSH, Ackerman MF, . 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants. Fundam Appl Toxicol 13:377–387.2515087
Giovanni L, Guglielmi G, Casini T, . 1992. Effect of ethanol chronic use on hepatotoxicity in rats exposed to tetrachloroethylene. Int J Tissue React XIV(6):281–285.
*Goldsworthy TL, Popp JA. 1987. Chlorinated hydrocarbon-induced peroxisomal enzyme activity in relation to species and organ carcinogenicity. Toxicol Appl Pharmacol 88:225–233.3564041
*Green T. 2000. Pulmonary toxicity and carcinogenicity of trichloroethylene: Species differences and modes of action. Environ Health Perspec 108:261–264.
*Green T, Odum J, Nash JA, . 1990. Perchloroethylene-induced rat kidney tumors: An investigation of the mechanisms involved and their relevance to humans. Toxicol Appl Pharmacol 103(1):77–89.1969182
*Guengerich FP, Kim D-H, Iwasaki M. 1991. Role of human cytochrome P-450 IIE1 in the oxidation of many low molecular weight cancer suspects. Chem Res Toxicol 4:168–179.1664256
Hansen H, DeRosa CT, Pohl H, . 1998. Public health challenges posed by chemical mixtures. Environ Health Perspect 106(Suppl. 6):1271–1280.9860881
Heindel JJ, Chapin RE, George J, . 1995. Assessment of the reproductive toxicity of a complex mixture of 25 groundwater contaminants in mice and rats. Fundam Appl Toxicol 25:9–19.7601330
*Herd PA, Lipsky M, Martin HF. 1974. Cardiovascular effects of 1,1,1-trichloroethane. Arch environ Health 28:221–227.
*IARC. 1995. Monographs on the evaluation of carcinogenic risks to humans. Vol. 63. Drycleaning, chlorinated solvent, and other industrial chemicals. World Health Organization, Lyon, France.
*IARC. 1999. Monographs on the evaluation of carcinogenic risks to humans. Vol. 71 (Part 2). Re-evaluation of some organic chemicals, hydrazine, and hydrogen peroxide. World Health Organization, Lyon, France.
IARC. 2001. IARC cancer databases and other resources. http://www.iarc.fr Accessed February 2001. World Health Organization, Lyon, France.
*Ikeda M, Imamura T. 1973. Biological half-life of trichloroethylene and tetrachloroethylene in human subjects. Int Arch Arbeitsmed 31:209–224.4593976
*IRIS. 2001. Files for 1,1-Dichloroethane, 1,1,1-trichloroethane, tetrachloroethylene, and trichloroethylene. Integrated Risk Information System, U.S. Environmental Protection Agency. February 15, 2001.
*Ivanetich KM, Van den Honert LH. 1981. Chloroethanes: Their metabolism by hepatic cytochrome P-450 in vitro. Carcinogenesis 2:697–702. (As cited in ATSDR 1995).7285278
Johnson BL, DeRosa CT. 1995. Chemical mixtures released from hazardous waste sites: implications for health risk assessment. Toxicology 105:145–156.8571353
*Jonker D, Woutersen RA, Feron VJ. 1996. Toxicity of mixtures of nephrotoxicants with similar or dissimilar mode of action. Food Chem Toxicol 34:1075–1082.9119318
*Kaneko T, Wang P-Y, Sato A. 1994. Enzymes induced by ethanol differently affect the pharmacokinetics of trichloroethylene and 1,1,1-trichloroethane. Occup Environ Med 51:113–119.8111458
Kawai T, Yamaoka K, Uchida Y, . 1991. Exposure of 1,1,1-trichloroethane and dose-related excretion of metabolites in urine of printing workers. Toxicol Lett 55:39–45.1998196
Kawakami T, Takano T, Araki R. 1988. Synergistic interaction of tri- and tetra- chloroethylene, hypoxia, and ethanol on the atrioventricular conduction of the perfused rat heart. Ind Health 26:25–33.3360617
*Kelafant GA, Berg RA, Schleenbaker R. 1994. Toxic encephalopathy due to 1,1,1-trichloroethane exposure. Am J Ind Med 25:439–446.8160661
*Klaassen CD, Plaa GL. 1966. Relative effects of various chlorinated hydrocarbons on liver and kidney function in mice. Toxicol Appl Pharmacol 9:139–151.5967557
*Kobayashi H, Hobara T, Kawamoto T, . 1987. Effect of 1,1,1-trichloroethane inhalation on heart rate and its mechanism: A role of autonomic nervous system. Arch Environ Health 42:140–143.3606210
*Koizumi A, Kastl PE Reitz RH, . 1986. Fate of ^14^C-trichloroethylene administered to rats in drinking water. DOW Chemical USA, Health and Environmental Sciences, Mammalian and Environmental Toxicology, Midland, Michigan. (As cited in ATSDR 1997a).
*Koizumi A, Kuami M, Ikeda M. 1982. In Vivo suppression of 1,1,1-trichloroethane metabolism by co-administered tetrachloroethylene: An inhalation study. Bull Environ Contam Toxicol 29:196–199.7126908
*Koizumi A, Kumai M, Ikeda M. 1983. Dose-dependent induction and suppression of liver mixed-function oxidase system in chlorinated hydrocarbon solvent metabolism. J Appl Toxicol 3:208–217.6643917
Kukongviriyapan V, Kukongviriyapan U, Stacey NH. 1990. Interference with hepatocellular substrate uptake by 1,1,1-trichloroethane and tetrachloroethylene. Toxicol Appl Pharmacol 102:80–90.2296773
Kyrklund T, Kjellstrand P, Haglid G. 1988. Effects of exposure to freon 11, 1,1,1-trichloroethane or perchloroethylene on the lipid and fatty-acid composition of rat cerebral cortex. Scand J Work Environ Health 14:91–94.3387963
*Lake BG. 1995. Peroxisome proliferation: current mechanisms relating to non-genotoxic carcinogenesis. Toxicol Lett 82/83:673–681.8597126
*Lal H, Shah HC. 1970. Effect of methylchloroform inhalation on barbiturate hypnosis and hepatic drug metabolism in male mice. Toxicol Appl Pharmacol 17:625–633.5528147
Lane R, Riddle BL, Borzelleca JF. 1982. Effects of 1,2-dichloroethane and 1,1,1-trichloroethane in drinking water on reproduction and development in mice. Toxicol Appl Pharmacol 63:409–421.7201685
*Lash LH, Fisher JW, Lipscomb JC, . 2000. Metabolism of trichloroethylene. Environ Health Perspec 108:177–200.
*Lee KM, Muralidhara S, White CA, . 2000. Mechanisms of the dose-dependent kinetics of trichloroethylene: Oral bolus dosing of rats. Toxicol Appl Pharmacol 164:55–64.10739744
*Lieber CS. 1997. Cytochrome P-4502E1: Its physiological and pathological role. Physiol Rev 77:517–544.9114822
Lock E. 1989. Mechanism of nephrotoxic action due to organohalogenated compounds. Toxicol Lett 46:93–106.2650039
*Mackay CJ, Campbell L, Samuel AM, . 1987. Behavioral changes during exposure to 1,1,1-trichloroethane: Time-course and relationship to blood solvent levels. Am J Ind Med 11:223–240.3826081
Maronpot RR, Anna CH, Devereux TR, . 1995. Considerations concerning the murine hepatocarcinogenicity of selected chlorinated hydrocarbons. Growth Factors and Tumor Promotions :305–323.
*McCall SN, Jurgens P, Ivanetich KM. 1983. Hepatic microsomal metabolism of the dichloroethanes. Biochem Pharmacol 32(2):207–213.6870950
*Mihic SJ, McQuilkin SJ, Eger EI, . 1994. Potentiation of γ-aminobutyric acid type A receptor-mediated chloride currents by novel halogenated compounds correlates with their abilities to induce general anesthesia. Molecular Pharmacol 46:851–857.
*Mikiskova H, Mikiska A. 1966. Trichloroethanol in trichloroethylene poisoning. Br J Ind Med 23:116–125.5929685
*Mitoma C, Steeger T, Jackson SE, . 1985. Metabolic disposition study of chlorinated hydrocarbons in rats and mice. Drug Chem Toxicol 8(3):183–194.4054011
*Monster AC, Boersma G, Duba WC. 1976. Pharmacokinetics of trichloroethylene in volunteers: Influence of workload and exposure concentration. Int Arch Occup Environ Health 38:87–102. (As cited in ATSDR 1997a).1002309
*Monster AC, Boersma G, Duba WC. 1979. Kinetics of trichloroethylene in repeated exposure of volunteers. Int Arch Occup Environ Health 42:283–292. (As cited in ATSDR 1997a).422269
Morel G, Ban M, Hettich D, . 1999. Role of SAM-dependent thiol methylation in the renal toxicity of several solvents in mice. J Appl Toxicol 19:47–54.9989477
*Morgan A, Black A, Belcher DR. 1972a. Studies on the absorption of halogenated hydrocarbons and their excretion in breath using 38Cl tracer techniques. Ann Occup Hyg 15: 273–282.4648240
*Morgan A, Black A, Walsh M, . 1972b. The absorption and retention of inhaled fluorinated hydrocarbon vapours. Int J Appl Radiat Isot 23:285–291.5043361
*Morgan DL, Cooper SW, Carlock DL. 1991. Dermal absorption of neat and aqueous volatile organic chemicals in the Fischer 344 rat. Environ Res 55:51–63.1855490
Mortensen B, Osvoll PO, Woldbaek T, . 1998. In vitro screening for metabolite interactions among frequently occurring binary mixtures of volatile organic chemicals in Norwegian occupational atmosphere. Pharmacol Toxicol 83:49–56.9783320
*Moslen MT, Reynolds ES, Szabo S. 1977. Enhancement of the metabolism and hepatotoxicity of trichloroethylene and perchloroethylene. Biochem Pharmacol 26:369–375.192239
*Mumtaz MM, Durkin PR. 1992. A weight-of-evidence approach for assessing interactions in chemical mixtures. Toxicol. Ind. Health 8: 377–406.7570620
*Mumtaz MM, De Rosa CT, Durkin PR. 1994. Approaches and challenges in risk assessments of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms and novel approaches. New York, NY: Academic Press, 565–597.
*Nakajima T, Wang R-S, Elovaara E, . 1992. A comparative study on the contribution of cytochrome P450 isozymes to metabolism of benzene, toluene and trichloroethylene in rat liver. Biochem Pharmacol 43:251–257.1739413
*Nakajima T, Wang R-S, Elovaara E, . 1993. Cytochrome P450-related differences between rats and mice in the metabolism of benzene, toluene and trichloroethylene in liver microsomes. Biochem Pharmacol 45(5):1079–1085.8461037
*Nakajima T, Wang R-S, Murayama N, . 1990. Three forms of trichloroethylene-metabolizing enzymes in rat liver induced by ethanol, phenobarbital, and 3-methylcholanthrene. Toxicol Appl Pharmacol 102:546–552.2315921
*NCI. 1977. Bioassay of tetrachloroethylene for possible carcinogenicity. National Cancer Institute. U.S. Department of Health, Education, and Welfare, Public Health Service, National Institutes of Health, DHEW Publ (NIH) 77–813. (As cited in ATSDR 1997b).
*Nolan RJ, Freshour NL, Rick DL. 1984. Kinetics and metabolism of inhaled methyl chloroform (1,1,1-trichloroethane) in male volunteers. Fundam Appl Toxicol 4:64–662. (As cited in ATSDR 1995).
*NTP. 1986. National Toxicology Program–technical report series no. 311. Toxicology and carcinogenesis studies of tetrachloroethylene (perchloroethylene) (CAS No. 127-18-4) in F344/N rats and B6C3F1 mice (inhalation studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, NIH publication no. 86-2567. (As cited in ATSDR 1997b).
*NTP. 2001. Ninth report on carcinogens. Revised January 2001. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program.
*Odum J, Green T, Foster JR, . 1988. The role of trichloroacetic acid and peroxisome proliferation in the differences in carcinogenicity of perchloroethylene in the mouse and rat. Toxicol Appl Pharmacol 92:103–112. (As cited in ATSDR 1997b).3341020
*Pegg DG, Zempel JA, Braun WH, . 1979. Disposition of (^14^C) tetrachloroethylene following oral and inhalation exposure in rats. Toxicol Appl Pharmacol 51:465–474. (As cited in ATSDR 1997b).538758
*Plaa GL. 1986. Toxic responses of the liver. In: Klaassen CD, Amdur MO, Doull J, eds. Casarett and Doull’s toxicology: The basic science of poisons. 3^rd^ ed. New York, NY: Macmillan Publishing Company, 236–309.
Plaa GL. 1988. Experimental evaluation of haloalkanes and liver injury. Fundam Appl Toxicol 10:563–570.3294072
Plaa GL, Larson RE. 1965. Relative nephrotoxic properties of chlorinated methane, ethane, and ethylene derivatives in mice. Toxicol Appl Pharmacol 7:37–44.14256601
*Quast JF, Calhoun LL, Frauson LE. 1988. 1,1,1-Trichloroethane formulation: A chronic inhalation toxicity and oncogenicity study in Fischer 344 rats and B6C3F1 mice. Fund Appl Toxicol 11:611–625.
*Reitz RH, Gargas ML, Mendrala AL, . 1996. In vivo and in vitro studies of perchloroethylene metabolism for physiologically based pharmacokinetic modeling in rats, mice, and humans. Toxicol Appl Pharmacol 136:289–306.8619237
*Reitz RH, McDougal JN, Himmelstein MW, . 1988. Physiologically based pharmacokinetic modeling with Methylchloroform: implications for interspecies, high dose/low dose, and dose route extrapolations. Toxicol Appl Pharmacol 62:390–401.
*Rhomberg LR. 2000. Dose–response analyses of the carcinogenic effects of trichloroethylene in experimental animals. Environ Health Perspec 108:343–358.
*Rosengren LE, Aurell A, Kjellstrand P, . 1985. Astrogliosis in the cerebral cortex of gerbils after long-term exposure to 1,1,1-trichloroethane. Scand J Work Environ Health 11:447–456.4095523
Samet JM. 1995. What can we expect from epidemiologic studies of chemical mixtures? Toxicology 105:307–314.8571367
*Sato A, Nakajima T, Koyama Y. 1980. Effects of chronic ethanol consumption on hepatic metabolism of aromatic and chlorinated hydrocarbons in rats. Br J Ind Med 37:382–386.7192567
*Sato A, Nakajima T, Koyama Y. 1981. Dose-related effects of a single dose of ethanol on the metabolism in rat liver of some aromatic and chlorinated hydrocarbons. Toxicol Appl Pharmacol 60:8–15.7281179
*Savolainen H, Pfaffli P, Tengen M, . 1977. Trichloroethylene and 1,1,1-trichloroethane: Effects on brain and liver after five days intermittent inhalation. Arch Toxicol 38:229–237.578726
*Schumann AM, Fox TR, Watanabe PG. 1982a. [14C]Methyl Chloroform (1,1,1-trichloroethane): Pharmacokinetics in rats and mice following inhalation exposure. Toxicol Appl Pharmacol 62:390–401.7071857
*Schumann AM, Fox TR, Watanabe PG. 1982b. A comparison of the fate of inhaled methyl chloroform (1,1,1-trichloroethane) following single or repeated exposure in rats and mice. Fundam Appl Toxicol 2:27–32.7185599
*Schumann AM, Quast JF, Watanabe PG. 1980. The pharmacokinetics and macromolecular interactions of perchloroethylene in mice and rats as related to oncogenicity. Toxicol Appl Pharmacol 55:207–219. (As cited in ATSDR 1997b).7423514
*Schwetz BA, Leong KJ, Gehring PJ. 1974. Embryo- and fetotoxicity of inhaled carbon tetrachloride, 1,1-dichloroethane and methyl ethyl ketone in rats. Toxicol Appl Pharmacol 28:452–464.4851838
*Scott CS, Cogliano VJ. 2000. Trichloroethylene health risks—State of the science. Environ Heath Perspec 108:159–160.
*Seiji K, Inoue O, In C, . 1989. Dose-excretion relationship in tetrachloroethylene-exposed workers and the effect of tetrachloroethylene co-exposure on trichloroethylene metabolism. Am J Ind Med 16:675–684.2596489
Simmons JE. 1996. Application of physiologically based pharmacokinetic modeling to combination toxicology. Food Chem Toxicol 34:1067–1073.9119317
Simmons JE, Berman E. 1989. Toxicity of complex waste mixtures: a comparison of observed and predicted lethality. J Toxicol Environ Health 27:275–286.2754754
Simmons JE, Yang RSH, Svendsgaard DJ, . 1994. Toxicology studies of a chemical mixture of 25 groundwater contaminants: hepatic and renal assessment, response to carbon tetrachloride challenge, and influence of treatment-induced water restriction. J Toxicol Environ Health 43:305–325.7966440
Simmons JE, Yang RSH, Berman E. 1995. Evaluation of the nephrotoxicity of complex mixtures containing organics and metals: Advantages and disadvantages of the use of real-world complex mixtures. Environ Health Perspect 103(Suppl. 1):67–71.
*Snyder R, Andrews LS. 1996. Toxic effects of solvents and vapors. In: Klaassen CD, Amdur MO, Doull J, eds. Casarett and Doull’s toxicology: The basic science of poisons. 5^th^ ed. New York, NY: McGraw-Hill Companies, 737–771.
*Stacey NH. 1989. Toxicity of mixtures of trichloroethylene, tetrachloroethylene and 1,1,1-trichloroethylene: similarity of in vitro to in vivo responses. Toxicol Ind Health 5(3):441–450.2763308
*Stewart RD, Dodd HC. 1964. Absorption of carbon tetrachloride, trichloroethylene, tetrachloroethylene, methylene chloride, and 1,1,1-trichloroethane through the human skin. Am Ind Hyg Assoc J 25:439–446. (As cited in ATSDR 1997b).14209666
*Stewart RD, Dodd HC, Gay HH, . 1970. Experimental human exposure to trichloroethylene. Arch Environ Health 20:64–71.5409662
*Stott WT, Quast JF, Watanabe PG. 1982. Pharmacokinetics and macromolecular interaction of trichloroethylene in mice and rats. Toxicol Appl Pharmacol 62:137–151. (As cited in ATSDR 1997a).7064149
Takahara K. 1989. Experimental study on toxicity of trichloroethane, Part 2, 1,1,1-and 1,1,2-trichloroethane in expired air and in urine of injected mice. Okayama Igakkai Zasshi 98:1091–1097.
Takano T, Miyazaki Y, Araki R. 1988. Interaction of 1,1,1-trichloroethane with the mixed-function oxidation system in rat liver microsomes. Xenobiotica 18(12):1457–1464.3245236
Thiele DL, Eigenbrodt EH, Ware AJ. 1982. Cirrhosis after repeated trichloroethylene and 1,1,1-trichloroethane exposure. Gastroenterology 83:926–929.7106523
*Toftgard R, Nilsen OG, Gustafsson J-A. 1981. Changes in rat liver microsomal cytochrome P-450 and enzymatic activities after the inhalation on n-hexane, xylene, methyl ethyl ketone and methylchloroform for four weeks. Scand J Work Environ Health 7:31–37.7313607
Toraason M, Breitenstein MJ, Wey HE. 1992. Reversible inhibition of intercellular communication among cardiac myocytes by halogenated hydrocarbons. Fundam Appl Toxicol 18:59–65.1601210
Umezu T, Yonemoto J, Soma Y, . 1997. Behavioral effects of trichloroethylene and tetrachloroethylene in mice. Pharmacol Biochem Behav 56(3):665–671.
*Vainio H, Savolainen H, Pfaffli P. 1978. Biochemical and toxicological effects of combined exposure to 1,1,1-trichloroethane and trichloroethylene on rat liver and brain. Xenobiotica 8:191–196.654314
*Von Euler G. 1994. Toluene and dipaminergic transmission. In: Isaacson RL, Jensen KE, eds. The Vulnerable Brain and Environmental Risks. Volume 3: Toxins in Air and Water. Plenum Press, New York, 301–321.
*Wartenberg D, Reyner D, Scott CS. 2000. Trichloroethylene and cancer: Epidemiologic evidence. Environ Health Perspec 108:161–176.
Werner M, Biner G, Dekant W. 1996. Sulfoxidation of mercapturic acids derived from tri-and tetrachloroethene by cytochromes P450 3A: a bioactivation reaction in addition to deacetylation and cysteine conjugate B-lyase mediated cleavage. Chem Res Toxicol 9:41–49.8924615
Yang RSH, Goehl TJ, Brown RD, . 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants I Chemistry Development. Fundam Appl Toxicol 13:366–376.2612771