# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ALT: alanine aminotransferase
AST: aspartate aminotransferase
ATSDR: Agency for Toxic Substances and Disease Registry
BINWOE: binary weight of evidence
bw: body weight
CYP: cytochrome P-450
DCVC: S-(1,2-dichlorovinyl)-L-cysteine
DCVG: S-(1,2-dichlorovinyl)glutathione
EPA: Environmental Protection Agency
IRIS: Integrated Risk Information System
kg: kilogram
L: liter
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
mg: milligram
mL: milliliter
mmol: millimole
MRL: Minimal Risk Level
NOAEL: no-observed-adverse-effect level
NPL: National Priorities List
PBPK: physiologically based pharmacokinetic
ppm: parts per million
RfC: Reference Concentration
RfD: Reference Dose
SDH: sorbitol dehydrogenase
U.S.: United States
WOE: weight of evidence
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to