# SUMMARY

1,1,1-Trichloroethane, 1,1-dichloroethane, trichloroethylene, and tetrachloroethylene frequently occur together in water samples collected from and in the vicinity of National Priorities List (NPL) hazardous waste sites and other sites assessed by the Agency for Toxic Substances and Disease Registry (ATSDR). These chemicals occur together more frequently than other volatile organic chemicals at the sites. In an unpublished survey of ATSDR Public Health Assessments for 210 NPL hazardous waste sites, this mixture of chemicals was found in groundwater samples from 95% of the sites, in soil samples from 23% of the sites, and in air samples from 12% of the sites. The purposes of this profile are (1) to evaluate data on the toxicology of mixtures of 1,1,1-trichloroethane, 1,1-dichloroethane, trichloroethylene, and tetrachloroethylene, (2) to evaluate data on the joint toxic actions (e.g., additive, less-than-additive, or greater-than-additive joint actions) of these chemicals in producing health hazards, and (3) to make recommendations for exposure-based assessments of the potential impact of joint toxic action of the mixture on public health.

There are no studies available that directly characterize health hazards and dose-response relationships for exposures to “whole” mixtures containing 1,1,1-trichloroethane, 1,1-dichloroethane, trichloroethylene, and tetrachloroethylene. Furthermore, physiologically based pharmacokinetic (PBPK) models have not been developed to predict dispositional and toxicological outcomes of joint action of mixtures of these four chemicals.

Exposure to the each of the individual chemicals can produce neurological impairment via parent chemical-induced physical and chemical changes in neuronal membranes and cause non-carcinogenic and carcinogenic responses (via reactive metabolites) in the liver and kidney of animals. No studies are available that directly examine joint toxic actions of binary or trinary mixtures of these chemicals on the nervous system, but additive joint action is plausible. Limited studies of joint toxic action of binary or trinary mixtures of these chemicals on the liver and kidney provide no evidence of greater-than-additive joint toxic actions. Additive joint action on the liver and kidney is plausible for binary combinations of each of the components, with the exception of limited evidence that tetrachloroethylene may inhibit the toxic action of trichloroethylene on the liver and kidney (Goldsworthy and Popp 1987; Seiji et al. 1989).

A component-based hazard index approach that assumes additive joint toxic action and uses ATSDR Minimal Risk Levels (MRLs) based on neurological impairment is recommended for exposure-based assessments of possible health hazards from exposure to mixtures of 1,1,1-trichloroethane, 1,1-dichloroethane, trichloroethylene, and tetrachloroethylene. There is no evidence to indicate that greater-than-additive interactions would cause liver and kidney effects to occur at exposure levels lower than those influencing the nervous system.