# Appendix E Chemical Structures of Mixture Components

1,1,1-Tetrachloroethane

equation

1,1-Dichloroethane

equation

Trichloroethylene

arrow

Tetrachloroethylene

arrow