# Appendix D Background Information for Tetrachloroethylene

## D.1 Toxicokinetics

Results from human and animal studies indicate that inhaled tetrachloroethylene is rapidly and efficiently absorbed by the lungs (ATSDR 1997b). For example, in rats given nose-only inhalation exposures to 50 or 500 ppm for 3 hours, near steady-state exhaled breath concentrations were attained within about 20 minutes and were proportional to concentration (Dallas et al. 1994b). Total uptake of tetrachloroethylene increased with exposure concentration, but was not linearly proportional to concentration, consistent with an influence of saturable metabolism on pulmonary uptake. Studies with rats, mice, and dogs indicate that ingested tetrachloroethylene is rapidly and completely absorbed (Dallas et al. 1994a, 1995; Frantz and Watanabe 1983; Pegg et al. 1979). When applied to the skin as a liquid, tetrachloroethylene also is rapidly absorbed. Tetrachloroethylene was detected in exhaled breath of humans shortly after immersion of one thumb in liquid tetrachloroethylene; a peak concentration was attained after about 40 minutes of exposure (Stewart and Dodd 1964). Other human studies indicate, however, that skin absorption of tetrachloroethylene vapor contributes only a small portion of absorbed body burden compared with pulmonary absorption.

Once absorbed, tetrachloroethylene is distributed widely throughout the body with preferential distribution to fatty tissue including maternal breast milk. Tetrachloroethylene is capable of crossing the placenta and reaching the developing fetus (ATSDR 1997b). Estimated partition coefficients for tetrachloroethylene in human tissues and liquids are 10–20 for blood/air, 1,450–1,650 for fat/air, and 125–159 for fat/blood; these values are consistent with ready partition into blood from air and preferential distribution to fatty tissue. In humans exposed to airborne concentrations up to 144 ppm for 4 hours, exhalation of unmetabolized tetrachloroethylene was the predominant route of elimination (Monster et al. 1979). Urinary excretion of metabolites represented a small percentage (1–2%) of absorbed doses. Half-lives of tetrachloroethylene in highly perfused tissue, muscle tissue, and fatty tissue of humans have been estimated at 12–16 hours, 30–40 hours, and 55 hours, respectively. In rats exposed to 10 ppm radiolabeled tetrachloroethylene, 68 and 3.6% of the absorbed radioactivity was exhaled as the parent material and carbon dioxide, respectively, over a 72-hour period; 24% of absorbed radioactivity was accounted for as nonvolatile urinary and fecal metabolites and 3–4% remained in the carcasses (Pegg et al. 1979). Metabolic saturation ensued with exposure to higher concentrations (600 ppm), as 88, 9, and 2% of the absorbed dose was accounted for by exhalation of parent chemical, urinary and fecal metabolites, and radioactivity remaining in the rat carcasses. The limited extent to which tetrachloroethylene is metabolized in rats is not dramatically influenced by induction of CYP isozymes. For example, in rats pretreated with phenobarbital before intraperitoneal injection with 1,474 mg/kg trichloroethylene/kg or 1,632 mg/kg tetrachloroethylene, rates of appearance of trichloroethylene metabolites in urine during 2-hour periods for up to 10 hours after injection were approximately 200- to 1,000-fold higher than rates for tetrachloroethylene metabolites (Ikeda and Imamura 1973). In contrast to humans and rats, mice appear to metabolize tetrachloroethylene more rapidly and completely. Following inhalation exposure of mice to 10 ppm radiolabeled tetrachloroethylene, urinary metabolites accounted for more than 80% of the absorbed dose (Schumann et al. 1980).

Metabolism of tetrachloroethylene to trichloroacetic acid, the principal metabolite, involves initial saturable catalysis by CYP isozymes to produce a reactive epoxide intermediate (tetrachloroethylene oxide), that can potentially bind to cellular macromolecules or rearrange to trichloroacetyl chloride (ATSDR 1997b). Trichloroacetyl chloride is further oxidized to trichloroacetic acid. The liver is the predominant site of and CYP2B1/2 is an important isozyme in tetrachloroethylene metabolism. Pretreatment of rats with phenobarbital (an inducer of CYP2B1/2) or Aroclor 1254 (an inducer of CYP2B1/2and 1A1/2 isozymes) before oral administration of 1,244 mg tetrachloroethylene/kg body weight increased the rates of urinary excretion of tetrachloroethylene metabolites by about 5- to 7-fold (Moslen et al. 1977).

Other metabolic pathways for tetrachloroethylene include one that leads from tetrachloroethylene oxide to oxalic acid and formic acid formation via catalysis by epoxide hydrase, and another involving initial conjugation of tetrachloroethylene with glutathione via glutathione transferase (ATSDR 1997b). The glutathione conjugate can be transported to the kidney where it can be hydrolyzed by β-lyase, producing a reactive thiol compound that is thought to bind to cellular macromolecules and lead to renal cytotoxicity. Small amounts of trichloroethanol have also been detected in the urine of workers exposed to tetrachloroethylene, but it has been proposed that the trichloroethanol derives from metabolism of trichloroethylene contamination of tetrachloroethylene rather than metabolism of tetrachloroethylene (ATSDR 1997b). Evidence is available that mice have a greater hepatic capacity for total tetrachloroethylene metabolism than rats, which in turn have a higher capacity than do humans.

PBPK models have been developed to describe the disposition of tetrachloroethylene in mice, rats, and humans, and to predict doses of proposed carcinogenic metabolites in target organs for the purpose of assessing human cancer risks based on rodent exposure-response data (ATSDR 1997b). Further development to link models for different chlorinated hydrocarbons that share metabolic pathways may be useful to predict dispositional and toxicological outcomes of possible interactions.

## D.2 Health Effects

Studies of occupationally exposed humans as well as of humans under acute controlled conditions indicate that neurological effects are the most predominant and sensitive effects of tetrachloroethylene (ATSDR 1997b). Observed effects include neurological symptoms such as headache, dizziness, and drowsiness in subjects exposed to 100 ppm for 7 hours, increased latency of pattern reversal visual-evoked brain potentials and performance deficits in tests of vigilance and eye-hand coordination in subjects exposed to 50 ppm, 4 hours/day for 4 days, and increased incidence of subjectively reported symptoms, such as dizziness and forgetfulness, in workers repeatedly exposed to average concentrations of about 20 ppm (ATSDR 1997b). Studies of animals exposed in utero (via oral exposure of mothers) indicate that tetrachloroethylene can adversely influence the developing nervous system, but studies to examine possible associations between occupational exposure of humans to tetrachloroethylene and increased risks for birth defects in offspring or reproductive effects such as menstrual disorders and spontaneous abortions provide only suggestive evidence that these types of effects may occur in humans (ATSDR 1997b). Limitations of the human reproductive and developmental toxicity studies include confounding exposures to other chemicals, inability to adjust for confounding factors, and lack of exposure data for individuals in the studies.

Based on analogy to other low molecular weight halogenated hydrocarbons, cardiac arrhythmias (associated with sensitization of the heart to epinephrine) from acute high level exposures to tetrachloroethylene may be expected to occur in humans. However, ATSDR (1997b) reviewed only one case of cardiac arrhythmia in a dry cleaning worker exposed to tetrachloroethylene, and a study of beagle dogs exposed to 5,000 or 10,000 ppm tetrachloroethylene found no evidence of heart sensitization to epinephrine.

Associations have also been made between human exposure to tetrachloroethylene and subtle renal effects in tetrachloroethylene-exposed workers (e.g., increased levels of enzymes or other proteins in urine) or liver effects in cases of people acutely exposed to high levels (e.g., enlarged liver or elevated serum ALT activity) (ATSDR 1997b). Renal effects have been observed in rats and mice chronically exposed to inhaled or ingested tetrachloroethylene. Rats and mice of both sexes exposed for 2 years to tetrachloroethylene air concentrations ≥200 and 100 ppm, respectively, showed dose-related renal tubular cell karyomegaly (nuclear enlargement) (NTP 1986). Nephropathy was observed in rats and mice exposed to gavage doses ≥471 and 386 mg/kg/day, respectively (NCI 1977). Kidney cancer responses observed in male rats following inhalation exposure to tetrachloroethylene (NTP 1986) have been proposed to involve accumulation of α-2µ-globulin, a process not relevant to humans (ATSDR 1997b).

Liver effects also have been observed in rats and mice repeatedly exposed to inhaled or ingested tetrachloroethylene, but mice appear more sensitive than rats (ATSDR 1997b). For example, hepatocellular degeneration and necrosis was found in male mice exposed for 2 years to air concentrations ≥100 ppm, and increased liver tumors developed in both sexes of mice under these conditions (NTP 1986). In contrast, rats exposed for 2 years to concentrations up to 400 ppm showed no increased incidence of non-neoplastic or neoplastic hepatic lesions (NTP 1986). In shorter-term experiments, mice exposed for 14–28 days to 200 or 400 ppm in air showed hepatocellular vacuolization and proliferation of peroxisomes, whereas rats under these conditions showed no proliferation of hepatic peroxisomes and less severe hepatocellular changes (i.e., hypertrophy) (Odum et al. 1988).

## D.3 Mechanisms of Action

Nervous system depression appear to be the most sensitive effects in humans from exposure to tetrachloroethylene, regardless of exposure route, and are thought to be caused predominately by the parent material (ATSDR 1997b). Hypothetical mechanisms of action include tetrachloroethylene-induced changes in the fatty acid pattern of neuronal membranes or the direct effect of incorporation of tetrachloroethylene in the membranes leading to an alteration in membrane structure and function. Possible contributions from metabolites cannot be conclusively ruled out, but appear unlikely given the slow rates at which tetrachloroethylene is expected to be metabolized in humans. Trichloroethanol, a metabolite of trichloroethylene that is a potent neurotoxic agent, does not appear to be a metabolite of tetrachloroethylene (ATSDR 1997b).

Liver and kidney effects observed in animals exposed to tetrachloroethylene have been proposed to be caused by reactive metabolic intermediates: a proposed reactive epoxide product of CYP catalysis in the liver; reactive oxygen species from proliferation of peroxisomes by trichloroacetic acid, the principal metabolite of tetrachloroethylene; and a reactive thiol product produced by hydrolysis of glutathione conjugates via β-lyase catalysis in the kidney (ATSDR 1997b). The latter reaction has been proposed to gain importance at high exposure concentrations when rates of elimination of the parent chemical in exhaled breath are maximized and CYP catalysis is saturated. The initial liver reaction leading to the thiol product, glutathione conjugation, competes for tetrachloroethylene as a substrate. The relevance of the observed rat kidney effects to humans has been questioned because glutathione conjugation activity was not detected in human liver preparations, β-lyase activities were low in human kidney preparations, and some of the kidney effects appear to be due to accumulation of α-2µ-globulin, a protein that is produced in male rats but not in female rats or humans of either sex (ATSDR 1997b). Evidence that metabolites may be involved in tetrachloroethylene hepatotoxicity includes the observation that pretreatment of rats with Aroclor 1254 before oral administration of 7.5 mmol tetrachloroethylene/kg (1,244 mg/kg) increased rates of urinary excretion of tetrachloroethylene metabolites and increased levels of serum AST compared with levels in nonpretreated rats (Moslen et al. 1977). The relevance of tetrachloroethylene-induced rodent liver effects to humans has been questioned based on evidence that humans produce little trichloroacetic acid from tetrachloroethylene (i.e., rates of total tetrachloroethylene metabolism in humans are low compared to rates in mice), mice and rats respond to trichloroacetic acid by induction of hepatocellular peroxisomes (that produce tissue damaging substances), and humans are relatively insensitive to the induction of hepatocellular peroxisomes (ATSDR 1997b; Lake 1995).

## D.4 Health Guidelines

ATSDR (1997b) derived an acute inhalation MRL of 0.2 ppm for tetrachloroethylene based on a NOAEL of 10 ppm and a LOAEL of 50 ppm for neurological effects (e.g., performance deficits in tests of vigilance and eye-hand coordination) in volunteers exposed 4 hours/day for 4 days (Altmann et al. 1992), and an uncertainty factor of 10 for human variability.

ATSDR (1997b) derived a chronic-duration inhalation MRL of 0.04 ppm for tetrachloroethylene based on a LOAEL of 15 ppm for significantly prolonged reaction times in women who worked in dry cleaning shops for an average period of 10 years (Ferroni et al. 1992) and an uncertainty factor of 100 (10 for the use of a LOAEL and 10 for human variability). Signs of mild kidney damage (increased urinary levels of lysozyme and β-glucuronidase) were found in another study of workers exposed to an average concentration of 10 ppm for an average of 14 years (Franchini et al. 1983). ATSDR (1997b) considered nervous system effects to be a more appropriate basis for the MRL and noted that the significance and adversity of the mild kidney effects were not clear.

ATSDR (1997b) did not derive an intermediate-duration inhalation MRL for tetrachloroethylene due to the lack of studies of neurological endpoints in humans exposed for intermediate durations. It was noted that liver enlargement was observed in mice exposed to 9 ppm, 24 hours/day for 30 days, but data in humans were considered more appropriate for MRL derivation because mice metabolize more tetrachloroethylene to trichloroacetic acid than humans and the peroxisomal proliferation response is greater in mice than humans.

ATSDR (1997b) derived an acute oral MRL of 0.05 mg/kg/day for tetrachloroethylene based on a LOAEL of 5 mg/kg/day for hyperactivity at 60 days of age in mice exposed to gavage doses for 7 days beginning at 10 days of age (Fredriksson et al. 1993) and an uncertainty factor of 1,000 (10 for the use of a LOAEL, 10 for extrapolating from animals to humans, and 10 for human variability).

ATSDR (1997b) did not derive intermediate- or chronic-duration oral MRLs for tetrachloroethylene due to the lack of suitable data. It was noted that intermediate-duration oral studies have observed liver effects in rats and mice and kidney effects in male rats, but these effects were not considered appropriate for MRL derivation due to apparent differences between humans and rodents in metabolism of tetrachloroethylene and in peroxisomal proliferation response, and indications that the kidney effects in male rats may be associated with accumulation of α-2µ-globulin, a male rat-specific protein (ATSDR 1997b).

EPA’s IRIS database (IRIS 2001) lists an RfD of 0.01 mg/kg/day for tetrachloroethylene based on a NOAEL of 20 mg/kg/day for hepatotoxic effects in mice exposed by gavage for 6 weeks (Buben and O’Flaherty 1985) and an uncertainty factor of 1,000 (10 for extrapolating from animals to humans, 10 for human variability, and 10 for extrapolating from subchronic exposure duration to chronic duration).

EPA’s IRIS database (IRIS 2001) does not list an RfC or a carcinogenicity assessment for tetrachloroethylene. As reviewed by ATSDR (1997b), the EPA Science Advisory Board in 1987 offered the opinion that the weight of evidence for tetrachloroethylene carcinogenicity was on a Group B2/C continuum (i.e., on the border between Group B2 and Group C). In 1991, another statement of this opinion was issued by the Science Advisory Board Executive Committee noting that tetrachloroethylene “should be considered to be an animal carcinogen, based on three endpoints in two species: liver tumors in male and female mice, kidney tumors in male rats, and, possibly, mononuclear cell leukemia in male and female rats” and that they did “not consider the evidence strong enough to classify this chemical as a probable human carcinogen.” EPA has yet to present a more recent position on the weight-of-evidence classification for trichloroethylene carcinogenicity, but is expected to present, in 2001, an updated carcinogenicity assessment for tetrachloroethylene based on its 1996 Proposed Guidelines for Carcinogen Risk Assessment. NTP (2001) lists tetrachloroethylene as reasonably anticipated to be a human carcinogen based on sufficient evidence of carcinogenicity in experimental animals. IARC (1995) concluded that tetrachloroethylene is probably carcinogenic to humans (Group 2A) based on limited evidence in humans and sufficient evidence in experimental animals. IARC (1995) made the following notes to accompany its conclusions:

“(i) Although tetrachloroethylene is known to induce peroxisome proliferation in mouse liver, a poor quantitative correlation was seen between peroxisome proliferations and tumor formation in the liver after administration of tetrachloroethylene by inhalation. The spectrum of mutations in protooncogenes in liver tumors from mice treated with tetrachloroethylene is different from that in liver tumors from mice treated with trichloroethylene.
(i) The compound induced leukemia in rats.
(ii) Several epidemiological studies showed elevated risks for oesophageal cancer, non-Hodgkin’s lymphoma, and cervical cancer.”