# Appendix C Background Information for Trichloroethylene

## C.1 Toxicokinetics

Studies of humans and rats indicate that inhaled trichloroethylene is rapidly and efficiently absorbed (ATSDR 1997a). Initial rates of uptake are high, but decrease as steady state conditions are approached. Studies in humans indicated that 37–64% of inhaled trichloroethylene was absorbed. Ingested trichloroethylene is rapidly and completely absorbed by the gastrointestinal tract (ATSDR 1997a). Fasted rats given gavage doses of 5–25 mg/kg trichloroethylene displayed peak blood concentrations within 6–10 minutes and absorbed >90% of the dose within 9 hours (D’Souza et al. 1985). Dermal absorption is rapid as indicated by observations of peak blood and exhaled air concentrations occurring within 5 minutes after a human subject immersed one hand in a trichloroethylene solution (ATSDR 1997a). Once absorbed, trichloroethylene is widely distributed to organs throughout the body (including the developing fetus) and, due to its lipophilic properties, can accumulate in fat to a limited degree (ATSDR 1997a). For example, 17 hours after a 6-hour/day, 4-day exposure of rats to 200 ppm, trichloroethylene was detected in perirenal fat and blood, but was not detected in other tissues (Savolainen et al. 1977).

Studies of humans and rodents indicate that inhaled trichloroethylene is eliminated from the body predominately in the urine as metabolites and to a lesser degree in exhaled breath as the parent chemical or other volatile metabolites such as trichloroethanol and carbon dioxide (ATSDR 1997a). For example, following single or sequential daily exposures of human subjects to 50–380 ppm, 11 and 2% of the dose was eliminated as trichloroethylene and trichloroethanol in exhaled breath; 58% was eliminated as urinary metabolites; and 30% was unaccounted for (Monster et al. 1976, 1979). Trichloroethylene was detected in exhaled breath of humans 18 hours after exposure ended due to the relatively long elimination half-life of trichloroethylene in fatty tissue (3.5–5 hours) compared with other tissues. Following inhalation exposure to radiolabeled trichloroethylene, mice excreted 75% of radioactivity in the urine and 9% as carbon dioxide in exhaled breath (Stott et al. 1982). Similar patterns of elimination were observed in mice and rats following oral administration of trichloroethylene (Koizumi et al. 1986).

The principal urinary metabolites of trichloroethylene in humans and animals are trichloroethanol, trichloroethanol-glucuronide, and trichloroacetic acid (ATSDR 1997a; Lash et al. 2000). Trichloroethylene is principally metabolized in the liver, but metabolism can also occur in Clara cells of the lungs and in the kidney. The principal pathway in humans and animals involves initial oxidation catalyzed by CYP isozymes (CYP2E1 and 2B1/2). It has been proposed that this reaction forms an epoxide intermediate (trichloroethylene oxide) that rapidly converts to chloral hydrate, but an alternative proposal indicates that chloral hydrate formation involves chlorine migration in an oxygenated trichloroethylene-CYP transition state (Lash et al. 2000). Chloral hydrate can be oxidized to trichloroacetic acid via chloral hydrate dehydrogenase or reduced to trichloroethanol via alcohol dehydrogenase. Trichloroacetic acid is a strong inducer of peroxisome proliferation and has been associated with hepatocarcinogenicity in rodents. Trichloroethanol can be conjugated with glucuronic acid via glucuronyl transferase to form trichloroethanol-glucuronide. Studies with human hepatic microsomes indicate that CYP2E1 is the predominant isozyme responsible for the initial steps in trichloroethylene metabolism, although there is evidence that CYP isozymes induced by phenobarbital (i.e., CYP2B1/2) may also be involved. At high exposure levels, enzymes involved in the main oxidative metabolic pathway can be saturated, leading to conjugation with glutathione to produce S-(1,2-dichlorovinyl)glutathione (DCVG). DCVG is acted on by γ-glutamyl transferase to remove glutamine, and the glycine is removed by the action of dipeptidases to yield S-(1,2-dichlorovinyl)-L-cysteine (DCVC). Cleavage of the cysteine by β-lyase in the kidney can lead to intermediates with reactive thiol groups that can react with cellular macromolecules leading to renal cytotoxicity and carcinogenicity.

Minor metabolic pathways arising from the initial intermediate, trichloroethylene oxide or the trichloroethylene-CYP transition state, include: (1) transformation to dichloroacetic acid through a dichloroacetyl chloride intermediate (this path appears to be more important in rodents than humans); (2) hydrolytic dechlorinations to form formic acid and carbon monoxide; and (3) hydrolytic dechlorinations to form carbon dioxide via, sequentially, glyoxylic acid chloride, glyoxylic acid and oxalic acid (ATSDR 1997a; Lash et al. 2000). Dichloroacetic acid can be conjugated with glutathione followed by sequential removal of glutamine and glycine to form dichlorovinyl-cysteine. Dichlorovinyl-cysteine can be transported to the kidney, where cleavage by β-lyase produces an intermediate with a reactive thiol group that can react with proteins and DNA leading to kidney cytotoxicity and kidney tumor development.

PBPK models have been developed for the disposition of trichloroethylene in mice, rats, and humans, including the prediction of target organ (e.g., liver, lung, brain, kidney) doses of biologically-active metabolites (ATSDR 1997a; Clewell et al. 2000; Fisher 2000). The models are being used to aid assessment of noncancer and cancer human health risks based on rodent exposure-response data (Barton and Clewell 2000; Rhomberg 2000).

## C.2 Health Effects

Results from studies of trichloroethylene-exposed humans and animals indicate that the primary targets for trichloroethylene noncarcinogens toxicity are the nervous system, liver, heart, and kidneys (ATSDR 1997a). The critical target (i.e., the target in which effects occur at the lowest exposure level) is expected to be the nervous system. Studies involving acute- or intermediate-duration inhalation or oral exposures have observed changes in neurobehavior in humans and animals at lower exposure levels (50–200 ppm) than those associated with liver effects (liver enlargement and cellular hypertrophy) and kidney effects (increased kidney weights and cytomegaly and karyomegaly in renal tubular epithelial cells) observed in animal studies (ATSDR 1997a). For example, Stewart et al. (1970) found no changes in liver function tests in humans who were exposed to 200 ppm for 7 hours/day for 5 days and reported experiencing headache, fatigue, and drowsiness. Effects on the heart appear to be restricted to cardiac arrhythmias due to trichloroethylene sensitization of the heart to epinephrine and other catecholamines.

Occupational exposure to trichloroethylene has been widespread due to its use in dry cleaning, for metal degreasing, and as a solvent for oils and resins. A recent article (Wartenberg et al. 2000) reviewed over 80 published papers and letters on the epidemiology of cancer in groups of people occupationally exposed to trichloroethylene. Elevated relative risks, ranging from 1.1 to 2.0, have been reported for kidney cancer, liver cancer, and non-Hodgkin’s lymphoma in several cohorts of workers repeatedly exposed to trichloroethylene in workplace air (see Wartenberg et al. 2000). Workers in these studies, however, were also exposed to other solvents (e.g., tetrachloroethylene). Accurate adjustment for this and other confounding factors is not possible from the available data. Wartenberg et al. (2000) concluded that there is “moderate support” for a causative relationship between exposure to trichloroethylene and cancer using Hill’s criteria of causation. Reflecting this assessment, IARC (1995) earlier concluded that the human evidence for trichloroethylene carcinogenicity is limited.

Chronic-duration animal studies have shown that cancer can be caused by inhalation or oral exposure to trichloroethylene, but do not point to a single target organ for increased tumor incidence. Carcinogenic responses have been observed in the liver, kidney, testes, lymphatic system, and lung, but the observed responses are not consistent across studies of different species and strains of animals (ATSDR 1997a).

In general, carcinogenic responses to trichloroethylene are thought to involve trichloroethylene metabolites (Bull 2000; Green 2000; Lash et at. 2000). This hypothesis is supported by observations that mice appear to be uniquely susceptible to trichloroethylene-induced liver and lung tumors and display higher rates of trichloroethylene metabolism than do rats. In contrast, rats appear to be uniquely susceptible to trichloroethylene-induced kidney damage and tumors. Based on its review of available data, ATSDR (1997a) concluded that there is adequate evidence to indicate that trichloroethylene is carcinogenic in mice, that the evidence for trichloroethylene carcinogenicity in rats is equivocal, and that further study is required to determine whether or not the processes that induce liver cancer in mice also operate in the human liver. EPA supported monographs on trichloroethylene health risks have been recently published and are being used to develop updated EPA health risk characterizations for trichloroethylene (Scott and Cogliano 2000).

## C.3 Mechanisms of Action

Like other solvents, nervous system effects from trichloroethylene are likely to involve disruption of neural membranes by the parent chemical, but trichloroethanol is also involved. In support of this hypothesis, Mikiskova and Mikiska (1966) reported that intraperitoneally administered trichloroethanol was 5–6 times more effective than trichloroethylene in altering electrophysiological variables associated with central nervous system depression in guinea pigs.

Trichloroethylene-induced cardiac arrhythmias are thought to involve parent-chemical sensitization of the heart to epinephrine-induced arrhythmias (ATSDR 1997a). In animals, chemicals that inhibited the metabolism of trichloroethylene increased the potency of trichloroethylene to induce cardiac arrhythmias, whereas chemicals enhancing trichloroethylene metabolism decreased its potency.

Metabolism of trichloroethylene is expected to produce cytotoxic and carcinogenic metabolites, including trichloroacetic acid, dichloroacetic acid, chloral hydrate, and 2-chloroacetaldehyde (ATSDR 1997a). Drinking water administration of trichloroacetic acid to rodents has produced carcinogenic changes in the liver that are associated with the proliferation of peroxisomes. Reactive oxygen species produced by peroxisomes are thought to be involved in a sequence of DNA damage, cytotoxicity, regenerative cell growth, and tumor development. Phenobarbital pretreatment and induction of hepatic CYP isozymes appear to be associated with enhancement of acute trichloroethylene hepatotoxicity in rodents (Allemand et al. 1978; Carlson 1973; Moslen et al. 1977; Nakajima et al. 1990), providing further support for the idea that metabolites are responsible for the hepatotoxicity of trichloroethylene. Trichloroethylene-induced liver cancer and peroxisomal proliferation have been associated with rapid metabolism of trichloroethylene to trichloroacetic acid in mice, but this metabolic pathway appears to be limited in rats and humans. Dichloroacetic acid has also been shown to produce liver cancer in mice, but its hepatocarcinogenicity has been hypothesized to involve some other, as yet unspecified, mechanism of action. The mouse liver displays much higher rates of metabolism of trichloroethylene, and is more susceptible to the hepatotoxicity and hepatocarcinogenicity of trichloroethylene, than do the livers of rats and humans. With chronic oral exposure to high doses of trichloroethylene by gavage, increased incidence of toxic nephrosis and renal tumors occurred in male rats, but in female rats the nephrosis was not accompanied by an increase in kidney tumors. Trichloroethylene-induced kidney damage has been proposed to involve conjugation products of trichloroethylene with glutathione. The conjugated products (e.g., dichlorovinyl-cysteine) can be hydrolyzed by β-lyase in the kidney forming a reactive thiol group that can react with cellular macromolecules and lead to cell damage. In support of this mechanistic hypothesis, chemical agents that inhibit β-lyase protected against dichlorovinyl-cysteine nephrotoxicity in rats (ATSDR 1997a).

## C.4 Health Guidelines

ATSDR (1997a) derived an acute inhalation MRL of 2 ppm for trichloroethylene based on a LOAEL of 200 ppm for subjective neurological symptoms such as fatigue and drowsiness in volunteers exposed 7 hours/day for 5 days (Stewart et al. 1970) and an uncertainty factor of 100 (10 for the use of a LOAEL and 10 to account for human variability).

ATSDR (1997a) derived an intermediate-duration inhalation MRL of 0.1 ppm for trichloroethylene based on a LOAEL of 50 ppm for decreased wakefulness during exposure, and decreased postexposure heart rate and slow-wave sleep in rats exposed for 8 hours/day, 5 days/week for 6 weeks (Arito et al. 1994), and an uncertainty factor of 300 (10 for using a LOAEL, 3 for extrapolating from rats to humans, 10 to account for human variability).

ATSDR (1997a) did not derive a chronic inhalation MRL for trichloroethylene due to the lack of suitable data.

ATSDR (1997a) derived an acute oral MRL of 0.2 mg/kg/day for trichloroethylene based on a LOAEL of 50 mg/kg/day for reduced rearing rate in rats and an uncertainty factor of 300 (10 for the use of a LOAEL, 10 for extrapolating from animals to humans, and 3 for human variability [a full factor of 10 was not used because pups were taken to represent a sensitive population]). The rats were exposed for 7 days beginning at 10 days of age and evaluated for locomotion, rearing, and total activity at 17 and 60 days of age (Fredriksson et al. 1993).

EPA’s IRIS database (IRIS 2001) does not list an RfD, an RfC, or a carcinogenicity assessment for trichloroethylene. As reviewed by ATSDR (1997a), the EPA Scientific Advisory Board in 1988 offered the opinion that the weight of evidence for trichloroethylene carcinogenicity was on a Group B2/C continuum (i.e., on the border between Group B2 and Group C). EPA has yet to present a more recent position on the weight-of-evidence classification for trichloroethylene carcinogenicity, but is currently evaluating several approaches to extrapolating from the animal tumor data for trichloroethylene to derive estimates of human cancer risks at environmentally relevant exposure levels (see Scott and Cogliano 2000). NTP (2001) listed trichloroethylene as reasonably anticipated to be a human carcinogen based on limited evidence of carcinogenicity from studies in humans, sufficient evidence of malignant tumor formation in experimental animals, and convincing relevant information that trichloroethylene acts through mechanisms indicating it would likely cause cancer in humans. IARC (1995) assigned trichloroethylene to Cancer Group 2A, probably carcinogenic to humans, based on limited evidence in humans and sufficient evidence in experimental animals. IARC (1995) noted that 1) although a hypothesis linking the formation of mouse liver tumors with peroxisome proliferation is plausible, trichloroethylene also induced tumors at other sites in mice and rats, and 2) several epidemiological studies showed elevated risks for cancer of the liver and biliary tract and for non-Hodgkin’s lymphoma.