# Appendix B Background Information for 1,1-Dichloroethane

## B.1 Toxicokinetics

Results from animal studies indicate that 1,1-dichloroethane is well absorbed in the pulmonary and gastrointestinal tracts and absorbed by the skin to some undetermined extent (ATSDR 1990). Results from studies with animals given intraperitoneal injections of radiolabeled 1,1-dichloroethane indicate that once absorbed, it can be distributed to tissues throughout the body. 1,1-Dichloroethane is poorly metabolized in the body and is rapidly excreted predominately unchanged in expired breath. For example, 48 hours after administration of high oral doses to rats (700 mg/kg) and mice (1,800 mg/kg), metabolism accounted for only about 7 and 29% of the administered doses, respectively (Mitoma et al. 1985). More than 90% of the administered dose in each species was exhaled unchanged or as carbon dioxide with 48 hours. It is likely that, at these high exposure levels, the metabolic capacity of the liver to metabolize 1,1-dichloroethane was saturated.

Studies with liver microsomes indicate that acetic acid is the major metabolite, and that 2,2-dichloroethanol, mono-, and dichloroacetic acid are minor metabolites of 1,1-dichloroethane (McCall et al. 1983). In vitro rates of production of acetic acid from 1,1-dichloroethane in rat hepatic microsomes were >1,000-fold higher than rates of production of the minor metabolites (McCall et al. 1983). Phenobarbital or ethanol pretreatment of rats produced increased rates of 1,1-dichloroethane metabolism (McCall et al. 1983; Sato et al.1980) suggesting that metabolism involves both CYP2B1/2 and CYP2E1 isozymes (Nakajima 1992). Metabolic steps have been proposed to involve initial hydroxylations at both of the carbons in 1,1-dichloroethane by CYP isozymes (McCall et al. 1983). Hydroxylation at the C-2 carbon is the minor pathway leading to, sequentially, 2,2-dichloroethanol, dichloroacetaldehyde, and dichloroacetic acid. Hydroxylation at the C-1 carbon, the major pathway, is expected to produce an unstable alpha haloalcohol that rearranges to form reactive acyl chlorides (acetyl chloride or chloroacetyl chloride), which have been proposed to react with cellular constituents leading to cellular dysfunctions (ATSDR 1990; McCall et al. 1983). No information was located to indicate whether the major and minor pathways for 1,1-dichloroethane may be mediated by different CYP isozymes. Under hypoxic conditions, reductive dechlorination of 1,1-dichloroethane can occur (presumably via CYP isozymes), leading to free radicals that can damage tissue, but the rates at which this occurs with 1,1-dichloroethane appear to be less than those associated with other more potent hepatotoxic chlorinated hydrocarbons such as carbon tetrachloride (ATSDR 1990).

## B.2 Health Effects

High level inhalation exposure to 1,1-dichloroethane is known to cause reversible nervous system impairment, and it has been used in the past as a gaseous anaesthetic agent (ATSDR 1990). Its use as an anesthetic agent was discontinued after it was discovered to induce cardiac arrhythmias at anesthetic doses (ATSDR 1990). Studies of rats, rabbits, guinea pigs, and cats intermittently exposed to vapor concentrations as high as 1,000 ppm for intermediate durations found no changes in several liver endpoints except for an increase in relative liver weight (ATSDR 1990). Evidence of renal toxicity (increased serum urea and creatinine, and crystalline precipitates in and dilation of kidney tubules) was found in cats exposed to 1,000 ppm, but not 500 ppm, in these studies. No renal toxicity was found in any of the other species (ATSDR 1990). In 78-week oral gavage studies with rats and mice, 1,1-dichloroethane produced increased incidences of hemangiosarcomas at various sites and mammary carcinomas in female rats exposed to 475 mg/kg/day, and liver carcinomas in male mice and benign uterine polyps in female mice exposed to 3,331 mg/kg/day (ATSDR 1990; IRIS 2001). These studies, however, were limited by low survival rates in all exposure and control groups, possibly due to pneumonia (IRIS 2001). Delayed skeletal development associated with maternal toxicity was the only effect noted in a study of pregnant rats exposed to up to 6,000 ppm, 7 hours/day during gestation days 6–15 (Schwetz et al. 1974).

## B.3 Mechanisms of Action

1,1-Dichloroethane, like other low molecular weight lipophilic halogenated hydrocarbons, is rapidly absorbed from the lungs and gastrointestinal tract, and eliminated rapidly upon cessation of exposure, since it readily crosses cellular membranes by passive diffusion (ATSDR 1990).

Like other agents that produce reversible anesthetic effects with high level inhalation exposure, nervous system impairment from acute exposure to 1,1-dichloroethane is expected to be caused by the interaction of the parent compound with components (e.g., phospholipids and/or proteins) of neuronal system membranes. The cardiac arrhythmias observed in humans inhaling high levels of 1,1-dichloroethane are likely caused by the parent compound sensitizing the heart to endogenous catecholamines, such as epinephrine, based on analogy to other low molecular weight chlorinated hydrocarbons (ATSDR 1990, 1995, 1997a, 1997b; Snyder and Andrews 1996).

The difference in hepatotoxic, renotoxic, and carcinogenic potency between 1,1-dichloroethane and its more potent isomer, 1,2-dichloroethane, appears to be associated with differences in metabolic disposition for the two isomers (McCall et al. 1983). Both isomers can be hydroxylated by CYP isozymes on either of the carbon atoms, but the 1,2-isomer can be conjugated with glutathione via glutathione transferases, leading to a reactive intermediate that is thought to be key to its toxic nature (McCall et al. 1983). The formation of reactive intermediates from conjugation of 1,1-dichloroethane with glutathione does not appear to occur; in contrast, glutathione conjugation may be a detoxification pathway for 1,1-dichloroethane (ATSDR 1990).

Hydroxylation of 1,1-dichloroethane at the C-1 carbon is hypothesized to produce an unstable alpha haloalcohol that rearranges to form reactive acyl chlorides (acetyl chloride or chloroacetyl chloride), which can react with cellular constituents leading to cellular dysfunctions (ATSDR 1990; McCall et al. 1983). Studies designed to examine if induction of hepatic CYP isozymes would influence the toxicity of 1,1-dichloroethane were not located, although phenobarbital pretreatment of rats has been demonstrated to enhance covalent binding of 1,1-dichloroethane metabolites to cellular macromolecules and increase rates of 1,1-dichloroethane metabolism in hepatic microsomes (Colacci et al. 1985). The role of glutathione conjugation as a detoxification pathway for 1,1-dichloroethane is consistent with the observation that addition of reduced glutathione to hepatic microsomal systems suppressed covalent binding of 1,1-dichloroethane metabolites to macromolecules (Colacci et al. 1985).

## B.4 Health Guidelines

ATSDR did not derive inhalation or oral MRLs for 1,1-dichloroethane due to the lack of appropriate data.

EPA does not list an RfD or an RfC for 1,1-dichloroethane on its IRIS (2001) database. EPA (IRIS 2001) classified 1,1-dichloroethane as a Group C chemical (Possible Human Carcinogen) based on no human data and limited evidence of carcinogenicity in two animal species (rats and mice) as shown by an increased incidence of mammary gland adenocarcinomas and hemangiosarcomas in female rats and an increased incidence of hepatocellular carcinomas and benign uterine polyps in mice. 1,1-Dichloroethane is not on the NTP (2001) list of agents known to be or reasonably anticipated to be human carcinogens. IARC (2001) has not assigned 1,1-dichloroethane to a cancer classification group.