# Appendix A Background Information for 1,1,1-Trichloroethane

## A.1 Toxicokinetics

As reviewed by ATSDR (1995), results from human and animal studies indicate that 1,1,1-trichloroethane is rapidly and efficiently absorbed by the respiratory tract, the gastrointestinal tract, and skin. For example, when human subjects held single breaths of air containing radiolabeled 1,1,1-trichloroethane for 15–40 seconds, alveolar concentrations decreased to between 10 and 20% of initial concentrations (Morgan et al. 1972a, 1972b), and 1,1,1-trichloroethane was detected in arterial blood of men within about 10 seconds after exposure to 240 or 350 ppm (Astrand et al. 1973). Several experiments with rats or mice administered oral doses of radiolabeled 1,1,1-trichloroethane found that recovered radioactivity in urine, expired air, and selected tissues accounted for between 88 and 99% of administered doses, indicating nearly complete absorption by the gastrointestinal tract (Mitoma et al. 1985; Reitz et al. 1988). In human subjects exposed to undiluted 1,1,1-trichloroethane by thumb or hand immersion or by topical application to the hand or forearm, 1,1,1-trichloroethane was quickly detected in alveolar air and/or in blood, indicating rapid absorption from the skin (ATSDR 1995). In rats, approximately 30% of undiluted 1,1,1-trichloroethane was absorbed within 24 hours of application to the skin under occluded conditions, whereas 12, 13, and 10% of saturated, two-thirds saturated, and one-third saturated aqueous solutions were absorbed under the same conditions (Morgan et al. 1991). Once absorbed, 1,1,1-trichloroethane is widely distributed throughout the body with preferential distribution to fatty tissue (ATSDR 1995). Regardless of route of exposure, 1,1,1-trichloroethane is predominately eliminated from the body via exhalation of the unchanged chemical (ATSDR 1995). It is rapidly cleared from the body; only trace amounts remain in tissues within days of termination of exposure of humans (Nolan et at. 1984) and animals (Mitoma et at. 1985).

1,1,1-Trichloroethane is metabolized at low rates via initial oxidative catalysis by CYP oxygenases to the predominant metabolites, trichloroethanol and trichloroacetic acid (ATSDR 1995). Phenobarbital-inducible CYP isozymes (CYP2B1/2) and ethanol-inducible isozymes (CYP2E1) are involved in the initial steps. Ethanol pretreatment of rats caused increased levels of hepatic CYP, increased rates of 1,1,1-trichloroethane metabolism (substrate disappearance) by hepatic microsomes, and increased rates of urinary excretion of trichloroacetic acid and trichloroethanol (Kaneko et at. 1994). Induced rates of 1,1,1-trichloroethane metabolism and urinary excretion of metabolites were much lower than rates for the highly metabolized halogenated hydrocarbon, trichloroethylene (Kaneko et al. 1994). Rates of 1,1,1-trichloroethane metabolism were also increased in rats pretreated with phenobarbital compared with untreated rats (Ivanetich and van den Honert 1981). Experiments with human liver microsomes and a CYP2E1-specific inhibitor indicate that CYP2E1 is the predominant CYP isozyme involved in metabolism of 1,1,1-trichloroethane and other chlorinated hydrocarbon solvents (Guengerich et at. 1991). Results from rat studies indicate that, under conditions of low oxygen supply, 1,1,1-trichloroethane can be reductively dechlorinated by phenobarbital-inducible CYP2B1/2 to reactive radical intermediates and eventually to acetylene, but this pathway appears to account for <1% of metabolized 1,1,1-trichloroethane and does not appear to represent a toxicologically significant pathway (Durk et al. 1992).

Results regarding the ability of 1,1,1-trichloroethane to induce its own metabolic machinery or induce hepatic levels of CYP isozyme are not consistent, but the weight of the available evidence reviewed in this paragraph suggests that repeated inhalation exposure to 1,1,1-trichloroethane will not markedly alter hepatic metabolism initially mediated by CYP isozymes, especially at administered dose levels below 500 mg/kg/day. Evidence that inhalation exposure to 1,1,1-trichloroethane induces hepatic CYP isozyme levels has been reported in rats exposed to 2,500–3,000 ppm for 24 hours (Fuller et al. 1970), rats exposed to 200–800 ppm for 240 hours (Koizumi et al. 1983), and mice exposed to about 3,000 ppm for up to 96 hours (Lal and Shah 1970). The degree of apparent induction was less than 2-fold in the rats and mice exposed to 2,500–3,000 ppm (Fuller et al. 1970; Lal and Shah 1970) and ranged from about 3- to 7-fold in rats exposed to 200–800 ppm (Koizumi et al. 1983). In contrast, no significant induction of hepatic CYP isozyme levels was found in rats exposed to 200 ppm, 6 hours/day for 5 days (Savolainen et al. 1977), or in rats exposed to 800 ppm, 6 hours/day, 5 days/week for 4 weeks (Toftgard et al. 1981). Schumann et al. (1982a, 1982b) reported that repeated inhalation exposure of rats or mice to 1,500 ppm 1,1,1-trichloroethane for 16 months did not alter the routes of excretion, the extent of metabolism, or the concentration of radioactivity in tissues after a 6-hour inhalation exposure to 1,500 ppm radiolabeled 1,1,1-trichloroethane, compared with rats exposed to radiolabeled chemical without pretreatment. In rats given oral doses of 0, 0.1, 0.5, 5.0, or 10.0 g/kg 1,1,1-trichloroethane for up to 12 days, hepatic microsomal activities of CYP2E1 (hydroxylation of p-nitrophenol to 4-nitrocatechol) and CYP2B1/2 (pentoxyresorufin-O-dealkylase) were induced only by the two highest doses, but none of these dose levels significantly changed hepatic levels of total CYP (Bruckner et al. 2000). In this study, the induction of CYP2E1 and CYP2B1/2 by the high doses (which also caused early mortalities in the rats), was modest (2- to 3-fold increases were observed) and transitory in time. Based on these observations Bruckner et al. (2000) concluded that induction of hepatic CYP isozymes by 1,1,1-trichloroethane, especially at administered dose levels <500 mg/kg/day, appears to be of limited toxicological significance to environmental or occupational exposures experienced by humans.

Metabolites of 1,1,1-trichloroethane are excreted in the urine, but, regardless of route of exposure, urinary elimination of metabolites represents only small fractions of absorbed doses (ATSDR 1995). For example, after rats ingested 116 mg /kg 1,1,1-trichloroethane in drinking water, the primary route of excretion was rapid elimination of unchanged parent material, with only 3% of the ingested dose accounted for by metabolism (Reitz et al. 1988). In another study with rats and mice given gavage doses of 1,1,1-trichloroethane, >85% of the administered dose was excreted unchanged in expired air (Mitoma et al. 1985). In humans exposed to 35 or 350 ppm for 6 hours, >91% of absorbed 1,1,1-trichloroethane was excreted unchanged in exhaled breath, 5–6% was metabolized and excreted as trichloroethanol and trichloroacetic acid, and <1% remained in the body after 9 days (Nolan et al. 1984).

Physiologically based pharmacokinetic models have been developed to describe the behavior of 1,1,1-trichloroethane in mice, rats, and humans (Bruckner et al. 1989; Dallas et al. 1989; Reitz et al. 1988). Linking of 1,1,1-trichloroethane PBPK models to PBPK models for other chemicals holds promise for predicting toxicological interactions, but awaits further research and development.

## A.2 Health Effects

Central nervous system depression is the predominant health effect associated with acute high-level inhalation exposure of humans and animals to 1,1,1-trichloroethane. Impaired performance in neurobehavioral function tests has been observed in humans at moderate air concentrations above about 175 ppm (Gamberale and Hultengren 1973; Mackay et al. 1987). Dizziness and initial signs of loss of coordination at concentrations are reported above 500 ppm, with general anesthesia at concentrations above 10,000 ppm (ATSDR 1995). Subtle residual neurological effects associated with repeated occupational exposures include impaired memory and deficits in balance in chronically exposed workers (Kelafant et al. 1994). In addition, changes in brain chemistry have been reported in animals exposed for intermediate durations (Rosengren et al. 1985). Neurological effects observed in animals exposed orally to 1,1,1-trichloroethane include hyperexcitability and narcosis in rats exposed to 5,000 mg/kg and changes in flash-evoked potentials and electroencephalographic patterns in rats exposed to 700 mg/kg for 4 days (ATSDR 1995). Peripheral neuropathy in several women has been associated with frequent and prolonged dermal occupational contact with 1,1,1-trichloroethane (ATSDR 1995).

Cardiac arrhythmias, associated with acute high-level inhalation exposure of humans and animals to 1,1,1-trichloroethane, are thought to involve sensitization of the heart to epinephrine (ATSDR 1995).

Acute high level exposure to 1,1,1-trichloroethane has also been associated with depressed blood pressure and transient myocardial injury (Aoki 1997; ATSDR 1995; Herd et al. 1974; Kobayashi et al. 1987).

Signs of liver damage, including increased serum levels of bilirubin and enzymes released from liver cells, have been observed in humans following high-level inhalation or oral exposure to 1,1,1-trichloroethane (ATSDR 1995). Studies of animals acutely or repeatedly exposed to high concentrations in air (>1,000 ppm) or high oral doses (>1,330 mg/kg) indicate that mild damage to liver tissue (e.g., increased serum ALT or AST levels or fatty changes associated with swelling of centrilobular hepatocytes) can be produced by exposure to 1,1,1-trichloroethane (ATSDR 1995). In male rats exposed to oral doses that produced about 30 or 50% mortality within 50 days of dosing (2.5 or 5.0 g/kg/day, respectively), pulmonary congestion was the only anomaly noted at necropsy and serum enzymes indicative of liver injury at 2 or 4 weeks were elevated to a small, but statistically significant extent, only at 5 g/kg/day (Bruckner et al. 2000). Rats exposed to 0.5 g/kg/day for 90 days showed no increased incidences of mortality or hepatic histopathological lesions (Bruckner et al. 2000). Results from a well-designed inhalation study of animals found no evidence for carcinogenic responses to 1,1,1-trichloroethane (Quast et al. 1988). Inconclusive results regarding 1,1,1-trichloroethane carcinogenicity were obtained in oral exposure studies of animals due to study limitations (ATSDR 1995).

Studies of women occupationally exposed to solvents, including 1,1,1-trichloroethane found no evidence for associations between exposure and adverse pregnancy outcomes, but minor fetotoxic effects (such as decreased fetal weights, increased minor soft tissue and skeletal anomalies, and delayed ossification) were observed in rats and rabbits exposed to moderate to high concentrations (>800 ppm) associated with maternal toxicity (ATSDR 1995). ATSDR (1995) suggested that additional developmental studies examining neurological endpoints in offspring may be warranted, but noted that a well-conducted study of rats exposed by gavage to doses as high as 750 mg/kg/day during gestation and lactation found no significant exposure-related changes in offspring examined at up to 2 months of age with a battery of neurobehavioral and neurophysiological tests (Dow 1993).

## A.3 Mechanisms of Action

Like other small molecular weight halogenated hydrocarbons, which are lipophilic, rapidly absorbed upon various routes of exposure, and eliminated readily upon cessation of exposure, 1,1,1-trichloroethane crosses cellular membranes by passive diffusion (ATSDR 1995).

Nervous system depression from 1,1,1-trichloroethane and other lipophilic solvents is thought to involve reversible intercalation (of the parent material and not metabolites) in lipid bilayers of nerve membranes (yielding changes in membrane fluidity) and/or reversible interactions with membrane proteins (yielding conformational changes) leading to altered ion transport, enzymic activities, and neurotransmitter receptor functions necessary for normal nerve impulses and regeneration of action potentials (ATSDR 1995; Balster 1998; Cruz et al. 1998; Engelke et al. 1996; Evans and Balster 1991; Franks and Lieb 1985, 1987; Korpela 1989; Mihic et al. 1994; von Euler 1994). The cardiac arrhythmias associated with acute high-level exposures are thought to involve parent material sensitization of the heart to epinephrine (ATSDR 1995). Other cardiotoxic effects of acute, high-level exposure to 1,1,1-trichloroethane, such as depressed blood pressure due to decreased heart rate, myocardial contractility, increased peripheral vascular dilation (i.e., decreased peripheral vascular resistance), or transient disturbance of pulmonary blood flow, have been hypothesized to involve parent material disruption of membrane-mediated processes regulating intracellular calcium levels or damage to pulmonary interstitium (Aoki et al. 1997; ATSDR 1995; Herd et al. 1974; Kobayashi et al. 1987).

The mechanism by which 1,1,1-trichloroethane may damage liver tissue is thought to be similar to that hypothesized to be involved in liver effects from other halogenated alkanes that are more potent hepatotoxic agents, such as 1,1,2-trichloroethane and carbon tetrachloride (ATSDR 1995). It has been proposed that the production of free radical metabolic intermediates formed by the oxidative catalytic action of CYP isozymes is responsible for the tissue damage via cleavage of the carbon-chlorine bond (ATSDR 1995). The free radicals are thought to react with unsaturated lipids and proteins in the endoplasmic reticulum of hepatocytes leading to morphological and functional changes in the organelle and eventually to cellular dysfunction (triglyceride accumulation) and necrosis. This hypothesis is supported by associated differences in metabolism and toxicity between 1,1,1-trichloroethane, which is poorly metabolized and has low toxic potency, and its isomer, 1,1,2-trichloroethane, which is extensively metabolized and has relatively high potency. Illustrating this difference in metabolism and potency, urinary excretion of metabolites accounted for >70% of administered doses of the potent 1,1,2-trichloroethane, whereas >85% of 1,1,1-trichloroethane was excreted unchanged in expired air (Mitoma et al. 1985).

It is unlikely that alteration of 1,1,1-trichloroethane metabolism will significantly change 1,1,1-trichloroethane hepatotoxicity or carcinogenicity given that the metabolism of 1,1,1-trichloroethane is so slow, that downstream enzymes may prevent the elevation of hepatic concentrations of any toxic metabolites formed, and that repair mechanisms may efficiently fix any damage to cellular macromolecules.

Furthermore, results from studies in which animals have been pretreated with phenobarbital or ethanol to enhance hepatic metabolism of 1,1,1-trichloroethane have not found consistent evidence that a potentiation of 1,1,1-trichloroethane hepatotoxicity may occur. In one study, pretreatment of rats with phenobarbital increased serum levels of AST and ALT following a 2-hour exposure to 11,600 ppm 1,1,1-trichloroethane compared with exposure without pretreatment (Carlson 1973). In contrast, Cornish et al. (1973) reported that phenobarbital pretreatment did not significantly increase serum AST levels after intraperitoneal injection of single doses of 1,1,1-trichloroethane (0.3–2.0 mL/kg) compared with exposure without pretreatment. Kaneko et al. (1994) showed that ethanol pretreatment of rats induced hepatic levels of total CYP (presumably CYP2E1, Lieber 1997) and increased rates of 1,1,1-trichloroethane metabolism, but the induced rates of 1,1,1-trichloroethane metabolism were still much lower than that of other more potent halogenated hydrocarbons (specifically trichloroethylene). Whereas ethanol induction of CYP2E1 increased rates of 1,1,1-trichloroethane metabolism at low exposure levels, it only affects rates of metabolism of trichloroethylene, a well-metabolized chemical, at high exposure levels (Kaneko et al. 1994).

## A.4 Health Guidelines

ATSDR (1995) derived an acute inhalation MRL of 2 ppm for 1,1,1-trichloroethane based on a LOAEL of 175 ppm for performance deficits in tests of psychomotor skills in humans exposed to controlled airborne concentrations of 1,1,1-trichloroethane for 3.5 hours (Mackay et al. 1987) and an uncertainty factor of 100 (10 for the use of a LOAEL and 10 to account for human variability).

ATSDR (1995) derived an intermediate-duration inhalation MRL of 0.7 ppm for 1,1,1-trichloroethane based on a NOAEL of 70 ppm and a LOAEL of 210 ppm for brain astrogliosis (increased brain levels of glial fibrillary acid protein) in gerbils exposed continuously for 3 months to vapors of 1,1,1-trichloroethane (Rosengren et al. 1985) and an uncertainty factor of 100 (10 for extrapolating from rats to humans and 10 to account for human variability).

ATSDR (1995) did not derive a chronic inhalation MRL or any oral MRLs for 1,1,1-trichloroethane due to the lack of appropriate studies (e.g., studies of subtle neurological effects associated with chronic inhalation exposure).

EPA does not list an RfD or an RfC for 1,1,1-trichloroethane on its IRIS database (IRIS 2001). EPA classified 1,1,1-trichloroethane as a Group D chemical (Not Classifiable as to Human Carcinogenicity) based on no human data and the lack of demonstrated carcinogenic effects in a chronic-duration, gavage-exposure rat study and an intermediate-duration, inhalation-exposure rat study. 1,1,1-Trichloroethane is not on the NTP (2001) list of chemicals known to be or reasonably anticipated to be human carcinogens. IARC (1999) assigned 1,1,1-trichloroethane to Cancer Group 3, not classifiable as to its carcinogenicity to humans, due to inadequate evidence in humans and experimental animals.