# 5 References

Abdel-Rahman A, Dechkovskaia AM, Goldstein LB, . 2004. Neurological deficits induced by malathion, DEET, and permethrin, alone or in combination in adult rats. J Toxicol Environ Health A 67(4):331–356. 10.1080/15287390490273569.14713564
Arora S, Kumar A. 2021. Mixture toxicity assessment of selected insecticides to silver perch fingerling, Bidyanus bidyanus. Ecotoxicol Environ Saf 226:112790. 10.1016/j.ecoenv.2021.112790.34653840
ATSDR. 1992. Public health assessment guidance manual. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2003a. Toxicological profile for pyrethrins and pyrethroids. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp155.pdf. March 29, 2013.
ATSDR. 2004a. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/interactionprofiles/IP-ga/ipga.pdf. April 2, 2013.
ATSDR. 2004b. Interaction profile for benzene, toluene, ethylbenzene, and xylenes (BTEX). Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/interactionprofiles/IP-btex/ip05.pdf. March 29, 2013.
ATSDR. 2018. Framework for assessing health impacts of multiple chemicals and other stressors (update). Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/interactionprofiles/ip-ga/ipga.pdf. February 20, 2023.
Belden JB, Lydy MJ. 2006. Joint toxicity of chlorpyrifos and esfenvalerate to fathead minnows and midge larvae. Environ Toxicol Chem 25(2):623–629. 10.1897/05-370r.1.16519327
Bosgra S, van Eijkeren JC, van der Schans MJ, . 2009. Toxicodynamic analysis of the inhibition of isolated human acetylcholinesterase by combinations of methamidophos and methomyl in vitro. Toxicol Appl Pharmacol 236(1):1–8. 10.1016/j.taap.2009.01.002.19371631
Burr SA, Ray DE. 2004. Structure-activity and interaction effects of 14 different pyrethroids on voltage-gated chloride ion channels. Toxicol Sci 77(2):341–346. 10.1093/toxsci/kfh027.14657519
Cao Z, Shafer TJ, Crofton KM, . 2011. Additivity of pyrethroid actions on sodium influx in cerebrocortical neurons in primary culture. Environ Health Perspect 119(9):1239–1246. 10.1289/ehp.1003394.21665567
Carter MK, Maddux B. 1974. Interaction of dichlorvos and anticholinesterases on the in vitro inhibition of human blood cholinesterases. Toxicol Appl Pharmacol 27:456–463. 10.1016/0041-008x(74)90217-8.4859365
Chen C, Wang Y, Zhao X, . 2014. The combined toxicity assessment of carp (Cyprinus carpio) acetylcholinesterase activity by binary mixtures of chlorpyrifos and four other insecticides. Ecotoxicology 23(2):221–228. 10.1007/s10646-013-1165-7.24363216
Choi J, Hodgson E, Rose RL. 2004. Inhibition of trans-permethrin hydrolysis in human liver fractions by chloropyrifos oxon and carbaryl. Drug Metabol Drug Interact 20(4):233–246. 10.1515/dmdi.2004.20.4.233.15663293
Costa LG. 2008. Toxic effects of pesticides. In: Klassen CD, ed. Casarett and Doull’s toxicology. The basic science of poisons. New York, NY: McGraw Hill Medical, 883–930.
Denton DL, Wheelock CE, Murray SA, . 2003. Joint acute toxicity of esfenvalerate and diazinon to larval fathead minnows (Pimephales promelas). Environ Toxicol Chem 22(2):336–341.12558165
de Perre C, Murphy TM, Lydy MJ. 2017. Mixture toxicity of phostebupirim and cyfluthrin: Species-specific responses. Environ Toxicol Chem 36(7):1947–1954. 10.1002/etc.3724.28019697
DuBois KP. 1961. Potentiation of the toxicity of organophosphorus compounds. Adv Pest Control Res 4:117–151.
EPA. 2006. Organophosphorus cumulative risk assessment 2006 update. Washington, DC: U. S. Environmental Protection Agency.
EPA. 2007a. Pesticide industry sales and usage. 2006 and 2007 market estimates. Washington, DC: U.S. Environmental Protection Agency. www.epa.gov/opp00001/pestsales/07pestsales/. March 29, 2013.
EPA. 2007b. Revised N-methyl carbamate cumulative risk assessment. Washington, DC: U.S. Environmental Protection Agency. https://archive.epa.gov/pesticides/reregistration/web/pdf/nmc_revised_cra.pdf. March 29, 2013.
EPA. 2011a. Memorandum: Pyrethroid cumulative risk assessment. U.S. Environmental Protection Agency. October 4, 2011.
EPA. 2011b. Memorandum: Draft science policy paper for the proposed common mechanism grouping for the pyrethrins and synthetic pyrethroids. U.S. Environmental Protection Agency. June 30, 2011.
EPA. 2011c. Memorandum: Re-evaluation of the FQPA safety factor for pyrethroid pesticides. U.S. Environmental Protection Agency. June 27, 2011.
Fai PBA, Tsobgny Kinfack JS, Tala Towa YJ. 2017. Acute effects of binary mixtures of Type II pyrethroids and organophosphate insecticides on Oreochromis niloticus. Ecotoxicology 26(7):889–901. 10.1007/s10646-017-1819-y.28593348
Flaskos J, Harris W, Sachana M, . 2007. The effects of diazinon and cypermethrin on the differentiation of neuronal and glial cell lines. Toxicol Appl Pharmacol 219(2–3):172–180. 10.1016/j.taap.2006.10.033.17239417
Gaughan LC, Engel JL, Casida JE. 1980. Pesticide interactions: Effects of organophosphorus pesticide on the metabolism, toxicity, and persistence of selected pyrethroid insecticides. Pestic Biochem Physiol 14:81–85.
Godin SJ, DeVito MJ, Hughes MF, . 2010. Physiologically based pharmacokinetic modeling of deltamethrin: development of a rat and human diffusion-limited model. Toxicol Sci 115(2):330–343. 10.1093/toxsci/kfq051.20200215
Gordon JJ, Leadbeater L, Maidment MP. 1978. The protection of animals against organophosphate poisoning by pretreatment with a carbamate. Toxicol Appl Pharmacol 48:207–216. 10.1016/s0041-008x(78)80045-3.
Gordon CJ, Herr DW, Gennings C, . 2006. Thermoregulatory response to an organophosphate and carbamate insecticide mixture: Testing the assumption of dose-additivity. Toxicology 217(1):1–13. 10.1016/j.tox.2005.08.014.16182429
Guo D, Wang Y, Qian Y, . 2017. Joint acute and endocrine disruptive toxicities of malathion, cypermethrin and prochloraz to embryo-larval zebrafish, Danio rerio. Chemosphere 166:63–71. 10.1016/j.chemosphere.2016.09.075.27684438
Gupta RC, Dettbarn WD. 1993. Role of carboxylesterases in the prevention and potentiation of N-methylcarbamate toxicity. Chem Biol Interact 87:295–303. 10.1016/0009-2797(93)90057-6.8343987
Ibrahim AEK, Mohamed Abdelrahman S, H KA E, . 2020. Single or combined exposure to chlorpyrifos and cypermethrin provoke oxidative stress and downregulation in monoamine oxidase and acetylcholinesterase gene expression of the rat’s brain. Environ Sci Pollut Res Int 27(11):12692–12703. 10.1007/s11356-020-07864-8.32006337
Institoris L, Papp A, Siroki O, . 2004. Comparative investigation of behavioral, neurotoxicological, and immunotoxicological indices in detection of subacute combined exposure with methyl parathion and propoxur in rats. Ecotoxicol Environ Saf 57(3):270–277. 10.1016/S0147-6513(03)00101-5.15041250
IRIS. 2013. Advanced search. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/search/index.cfm. March 28, 2013.
Johnstone AFM, Strickland JD, Crofton KM, . 2017. Effects of an environmentally-relevant mixture of pyrethroid insecticides on spontaneous activity in primary cortical networks on microelectrode arrays. Neurotoxicology 60:234–239. 10.1016/j.neuro.2016.05.005.27177986
Keplinger ML, Deichmann WB. 1967. Acute toxicity of combinations of pesticides. Toxicol Appl Pharmacol 10:585–595.
Kok FN, Hasirci V. 2004. Determination of binary pesticide mixtures by an acetylcholinesterase-choline oxidase biosensor. Biosens Bioelectron 19:661–665. 10.1016/j.bios.2003.07.002.14709383
Laetz CA, Baldwin DH, Collier TK, . 2009. The synergistic toxicity of pesticide mixtures: Implications for risk assessment and the conservation of endangered Pacific salmon. Environ Health Perspect 117(3):348–353. 10.1289/ehp.0800096.19337507
Latuszynska J, Luty S, Raszewski G, . 2003. Neurotoxic effect of dermally applied chlorpyrifos and cypermethrin. Reversibility of changes. Ann Agric Environ Med 10(2):197–201.14677911
McDaniel KL, Padilla S, Marshall RS, . 2007. Comparison of acute neurobehavioral and cholinesterase inhibitory effects of N-methylcarbamates in rat. Toxicol Sci 98(2):552–560. 10.1093/toxsci/kfm114.17504769
Mirfazaelian A, Kim KB, Anand SS, . 2006. Development of a physiologically based pharmacokinetic model for deltamethrin in the adult male Sprague-Dawley rat. Toxicol Sci 93(2):432–442. 10.1093/toxsci/kfl056.16831841
Miyaoka T, Takahashi H, Tsuda S. 1984. Potentiation of acute toxicity of 2-sec-butylphenyl N-methylcarbamate (PBMC) by fenthion in mice. Fundam Appl Toxicol 4:802–807.6510612
Moser VC, Casey M, Hamm A, . 2005. Neurotoxicological and statistical analyses of a mixture of five organophosphorus pesticides using a ray design. Toxicol Sci 86(1):101–115. 10.1093/toxsci/kfi163.15800032
Moser VC, Simmons JE, Gennings C. 2006. Neurotoxicological interactions of a five-pesticide mixture in preweanling rats. Toxicol Sci 92(1):235–245. 10.1093/toxsci/kfj189.16611628
Motomura H, Narahashi T. 2001. Interaction of tetramethrin and deltamethrin at the single sodium channel in rat hippocampal neurons. NeuroToxicology 22:329–339. 10.1016/s0161-813x(01)00023-7.11456334
Murphy SD, DuBois KP. 1957. Quantitative measurement of inhibition of the enzymatic detoxification of malathion by EPN (ethyl p-nitrophenyl thionobenzenephosphonate). Proc Soc for Exp Biol Med 96(3):813–818. 10.3181/00379727-96-23617.
Mwanza JC, Lyke DF, Hertzberg RC, . 2012. Cholinesterase inhibition and depression of the photic after discharge of flash evoked potentials following acute or repeated exposures to a mixture of carbaryl and propoxur. Neurotoxicology 33(3):332–346. 10.1016/j.neuro.2012.02.006.22353443
Nong A, Tan YM, Krolski ME, . 2008. Bayesian calibration of a physiologically based pharmacokinetic/pharmacodynamic model of carbaryl cholinesterase inhibition. J Toxicol Environ Health A 71(20):1363–1381. 10.1080/15287390802271608.18704829
Ortiz D, Yanez L, Gomez H, . 1995. Acute toxicological effects in rats treated with a mixture of commercially formulated products containing methyl parathion and permethrin. Ecotoxicol Environ Saf 32(2):154–158. 10.1006/eesa.1995.1096.8575360
Padilla S. 2006. Cumulative effects of organophosphorus or carbamate pesticides. In: Gupta RC, ed. Toxicology of organophosphate and carbamate compounds. Boston, MA: Elsevier Academic Press, 607–615.
Padilla S, Marshall RS, Hunter DL, . 2005. Time course and dose response assessment of cholinesterase (CHE) inhibition in adult rats treated acutely with carbaryl, methomyl, methiocarb, oxamyl or propoxur. Toxicologist 84(S-1):397.
Padilla S, Setzer W, Marshall RS, . 2006. A dose response study of the toxicity of a mixture of 7 N-methyl carbamate pesticides in adult male rats. Toxicologist 90(1):9.
Ray DE, Fry JR. 2006. A reassessment of the neurotoxicity of pyrethroid insecticides. Pharmacol Ther 111:174–193.16324748
Padilla S, Marshall RS, Hunter DL, . 2007. Time course of cholinesterase inhibition in adult rats treated acutely with carbaryl, carbofuran, formetanate, methomyl, methiocarb, oxamyl or propoxur. Toxicol Appl Pharmacol 210:202–209. 10.1016/j.taap.2006.11.010.
Ray DE, Burr SA, Lister T. 2006. The effects of combined exposure to the pyrethroids deltamethrin and S-bioallethrin on hippocampal inhibition and skeletal muscle hyperexcitability in rats. Toxicol Appl Pharmacol 216(2):354–362. 10.1016/j.taap.2006.06.005.16875707
Romero A, Ares I, Ramos E, . 2015. Evidence for dose-additive effects of a type II pyrethroid mixture. In vitro assessment. Environ Res 138:58–66. 10.1016/j.envres.2015.02.008.25688004
Sams C, Jones K. 2011. Human volunteer studies investigating the potential for toxicokinetic interactions between the pesticides deltamethrin; pirimicarb and chlorpyrifos-methyl following oral exposure at the acceptable daily intake. Toxicol Lett 200(1–2):41–45. 10.1016/j.toxlet.2010.10.012.21035527
Scholz NL, Truelove NK, Labenia JS, . 2006. Dose-additive inhibition of Chinook salmon acetylcholinesterase activity by mixtures of organophosphate and carbamate insecticides. Environ Toxicol Chem 25(5):1200–1207. 10.1897/05-030r1.1.16704049
Seume FW, O’Brien RD. 1960. Metabolism of malathion by rat tissue preparations and its modification by EPN. Agric Food Chem 8:36–41.
Shen W, Lou B, Xu C, . 2020. Lethal toxicity and gene expression changes in embryonic zebrafish upon exposure to individual and mixture of malathion, chlorpyrifos and lambda-cyhalothrin. Chemosphere 239:124802. 10.1016/j.chemosphere.2019.124802.31521933
Soderlund DM, Clark JM, Sheets LP, . 2002. Mechanisms of pyrethroid neurotoxicity: Implications for cumulative risk assessment. Toxicology 171:3–59. 10.1016/s0300-483x(01)00569-8.11812616
Song JH, Narahashi T. 1996. Differential effects of the pyrethroid tetramethrin on tetrodotoxin-sensitive and tetrodotoxin-resistant single sodium channels. Brain Res 712:258–264. 10.1016/0006-8993(95)01449-7.8814900
Song JH, Nagata K, Tatebayashi H, . 1996. Interactions of tetramethrin, fenvalerate and DDT at the sodium channel in rat dorsal root ganglion neurons. Brain Res 708(1–2):29–37. 10.1016/0006-8993(95)01239-7.8720856
Starr JM, Scollon EJ, Hughes MF, . 2012. Environmentally relevant mixtures in cumulative assessments: an acute study of toxicokinetics and effects on motor activity in rats exposed to a mixture of pyrethroids. Toxicol Sci 130(2):309–318. 10.1093/toxsci/kfs245.22872056
Syberg K, Elleby A, Pedersen H, . 2008. Mixture toxicity of three toxicants with similar and dissimilar modes of action to Daphnia magna. Ecotoxicol Environ Saf 69(3):428–436. 10.1016/j.ecoenv.2007.05.010.17631961
Tabarean IV, Narahashi T. 1998. Potent modulation of tetrodoxin-sensitive and tetrodotoxin-resistant sodium channels by the type II pyrethroid deltamethrin. J Pharmacol Exp Ther 284(3):958–965.9495855
Takahashi H, Miyaoka T, Tsuda S, . 1984. Potentiated toxicity of 2-sec-butylphenyl methylcarbamate (BPMC) by 0,0,-dimethyl 0-(3-methyl-4-nitrophenyl) phosphorothioate (fenitrothion) in mice. Relationship between acute toxicity and metabolism of BPMC. Fundam Appl Toxicol 4:718–723. 10.1016/0272-0590(84)90092-7.6510602
Takahashi H, Kato A, Yamashita E, . 1987. Potentiations of N-methylcarbamate toxicities by organophosphorus insecticides in male mice. Fundam Appl Toxicol 8:139–146. 10.1016/0272-0590(87)90112-6.2951289
Tang J, Cao Y, Rose RL, . 2002. In vitro metabolism of carbaryl by human cytochrome P450 and its inhibition by chlorpyrifos. Chem Biol Interact 141(3):229–241. 10.1016/s0009-2797(02)00074-1.12385721
Timchalk C. 2006. Physiologically based pharmacokinetic modeling of organophosphorus and carbamate pesticides. In: Gupta RC, ed. Toxicology of organophosphate and carbamate compounds. Boston, MA: Elsevier Academic Press, 103–125.
Timchalk C, Poet TS. 2008. Development of a physiologically based pharmacokinetic and pharmacodynamic model to determine dosimetry and cholinesterase inhibition for a binary mixture of chlorpyrifos and diazinon in the rat. Neurotoxicology 29(3):428–443. 10.1016/j.neuro.2008.02.004.18394709
Timchalk C, Nolan RJ, Mendrala AL, . 2002. A physiologically based pharmacokinetic and pharmacodynamic (PBPK/PD) model for the organophosphate insecticide chlorpyrifos in rats and humans. Toxicol Sci 66:34–53. 10.1093/toxsci/66.1.34.11861971
Timchalk C, Poet TS, Hinman MN, . 2005. Pharmacokinetic and pharmacodynamic interaction for a binary mixture of chlorpyrifos and diazinon in the rat. Toxicol Appl Pharmacol 205:31–42. 10.1016/j.taap.2004.09.004.15885262
Tornero-Velez R, Mirfazaelian A, Kim KB, . 2010. Evaluation of deltamethrin kinetics and dosimetry in the maturing rat using a PBPK model. Toxicol Appl Pharmacol 244(2):208–217. 10.1016/j.taap.2009.12.034.20045431
Tsuda S, Miyaoka T, Iwasaki M. 1984. Pharmacokinetic analysis of increased toxicity of 2-sec-butylphenyl methylcarbamate (BPMC) by fenitrothion pre-treatment in mice. Fundam Appl Toxicol 4:724–730. 10.1016/0272-0590(84)90093-9.6510603
Wang Y, Chen C, Zhao X, . 2015. Assessing joint toxicity of four organophosphate and carbamate insecticides in common carp (Cyprinus carpio) using acetylcholinesterase activity as an endpoint. Pestic Biochem Physiol 122:81–85. 10.1016/j.pestbp.2014.12.017.26071811
Wang Y, Lv L, Yu Y, . 2017. Single and joint toxic effects of five selected pesticides on the early life stages of zebrafish (Denio rerio). Chemosphere 170:61–67. 10.1016/j.chemosphere.2016.12.025.27974272
Wolansky MJ, Gennings C, DeVito MJ, . 2009. Evidence for dose-additive effects of pyrethroids on motor activity in rats. Environ Health Perspect 117(10):1563–1570. 10.1289/ehp.0900667.20019907
Zhan W, Weng H, Liu F, . 2022. Joint toxic effects of phoxim and lambda-cyhalothrin on the small yellow croaker (Larimichthys polyactis). Chemosphere 307(Pt 4):136203. 10.1016/j.chemosphere.2022.136203.36037960
Zhang X, Tsang AM, Okino MS, . 2007. A physiologically based pharmacokinetic/pharmacodynamic model for carbofuran in Sprague-Dawley rats using the exposure-related dose estimating model. Toxicol Sci 100(2):345–359. 10.1093/toxsci/kfm232.17804862
Zhang ZY, Yu XY, Wang DL, . 2010. Acute toxicity to zebrafish of two organophosphates and four pyrethroids and their binary mixtures. Pest Manag Sci 66(1):84–89. 10.1002/ps.1834.19728319
Zhang J, Liu L, Ren L, . 2017. The single and joint toxicity effects of chlorpyrifos and beta-cypermethrin in zebrafish (Danio rerio) early life stages. J Hazard Mater 334:121–131. 10.1016/j.jhazmat.2017.03.055.28407539