# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ATSDR: Agency for Toxic Substances and Disease Registry
BINWOE: binary weight-of-evidence
BPMC: 2-sec-butylphenyl N-methylcarbamate
ChE: acetylcholinesterase
BMD: benchmark dose
BMDL: benchmark dose limit
BTEX: benzene, toluene, ethylbenzene, and xylene
CYP: cytochrome P450
DEF: S,S,S-tributyl phosphorotrithioate
DEET: N,N-diethyl-m-toluamide
DTHHS: Division of Toxicology and Human Health Sciences
EPA: U.S. Environmental Protection Agency
EPN: O-ethyl O-(4-nitrophenyl) phenyl phosphonothioate
ERDEM: exposure-related dose estimating model
FQPA: U.S. Food Quality and Protection Act
GABA: gamma-aminobutyric acid
GD: gestation day
HI: hazard index
HQ: hazard quotient
IARC: International Agency Research on Cancer
IR: interactive ratio
IRIS: Integrated Risk Information System
iso-OMPA: tetraisoproylpyrophosphoramide
kg: kilogram
LC_50_: median lethal concentration
LD_50_: median lethal dose
LOAEL: lowest-observed-adverse-effect level
mg: milligram
MOE: margin of exposure
MPMC: 3,4-dimethylphenyl N-methylcarbamate
MRL: Minimal Risk Level
MTMC: 3-methylphenyl N-methylcarbamate
NAC: 1-naphthyl N-methylcarbamate
NOAEL: no-observed-adverse-effect level
NTE: neuropathy target esterase
NTP: National Toxicology Program
OPIDP: organophosphate-induced delayed polyneuropathy
OPP: U.S. EPA Office of Pesticide Programs
PBPK/PD: physiologically based pharmacokinetic/pharmacodynamic
PhAD: photic after discharge
PND: postnatal day
POD: point of departure
ppm: parts per million
RBC: red blood cell
RfD: reference dose
RPF: relative potency factor
TTD: target-organ toxicity dose
TU: toxic unit
U.S.: United States
VGSC: voltage-gated sodium channel
XMC: 3,5-dimethylphenyl N-methylcarbamate
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to