# SUMMARY

The purpose of this profile is to investigate the possible joint actions of pyrethroid insecticides, organophosphorus insecticides and carbamate insecticides on neurological end points in humans. In assessing the available information on possible interactions among these chemicals, this profile concludes with recommendations for conducting screening-level assessments of public health concerns from joint exposure to mixtures of these chemical classes.

ATSDR recommends that the default assumption of dose-additive joint action at shared targets of toxicity (i.e., effects on neurological end points) be used for screening-level assessments of the potential adverse health outcomes from concurrent oral exposures to mixtures of pyrethroids, organophosphorus and carbamate insecticides. The assessments should be accompanied by qualitative descriptions of weight-of-evidence evaluations of available interaction data:

1 greater-than-additive action on neurological end points is possible between certain pyrethroid and organophosphorus insecticides;
2 the available data are inadequate to assess the possible direction of interactions between pyrethroids and carbamates; and
3 limitations in evidence for greater-than-additive interactions support the assumption of dose additivity of carbamate and organophosphorus insecticides on neurological end points.
4 BINWOEs include scoring categories that address uncertainty in the data.

Overall, the evidence is not compelling to move from a dose-additive approach for screening-level assessments. The evaluations indicate that greater-than-additive interactions between certain pyrethroid and organophosphorus insecticides are possible, but key findings in mammals come from a study of potentiation of fenvalerate lethality in rats pretreated with certain organophosphorus insecticides (Gaughan et al. 1980). The relevance of these findings to relatively low (nonlethal) environmental concurrent exposure to pyrethroid and organophosphorus insecticides is not well understood.