# PEER REVIEW

A peer review panel was assembled for this profile. The panel consisted of the following members:

1. AMJ Ragas, Ph.D., Department of Environ Science, Faculty of Science, Radboud University Nijmegen, Netherlands.
2. Richard C. Hertzberg, Ph.D., Emory University, School of Public Health, Biomathematics Consulting, Atlanta, GA, USA.
3. Jane Ellen Simons, Ph.D., NHEERL, U.S. Environmental Protection Agency, Raleigh, NC, USA.
4. Bob Krieger, Ph.D., Department of Entomology, University of California, Riverside, CA, USA.

All reviewers were selected in conformity with the conditions for peer review specified in CERCLA Section 104(I)(13).

Scientists from ATSDR have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.