# Appendix E Mixtures of Insecticides at Hazardous Waste Sites

Table E-1 Sites with Two of the Types of Pesticides^a^

Site event key^b^ | Type | Contaminant | CAS number
AZR000041764 | Organophosphorus | Chlorpyrifos | 2921-88-2
AZR000041764 | Pyrethroid | Permethrin | 52645-53-1
CAD000629998 | Carbamate | Carbaryl | 63-25-2
CAD000629998 | Carbamate | Carbofuran | 1563-66-2
CAD000629998 | Organophosphorus | Diazinon | 333-41-5
CAD000629998 | Organophosphorus | Dimethoate | 60-51-5
CAD000629998 | Organophosphorus | Disulfoton | 298-04-4
CAD000629998 | Organophosphorus | Ethion | 563-12-2
CAD000629998 | Organophosphorus | Guthion | 86-50-0
CAD000629998 | Organophosphorus | Malathion | 121-75-5
CAD000629998 | Organophosphorus | Methyl parathion | 298-00-0
CAD000629998 | Organophosphorus | Naled | 300-76-5
CAD000629998 | Organophosphorus | S,S,S-Tributyl phosphorotrithioate | 78-48-8
CAD071530380 | Carbamate | Carbaryl | 63-25-2
CAD071530380 | Carbamate | Methomyl | 16752-77-5
CAD071530380 | Carbamate | Propoxur | 114-26-1
CAD071530380 | Organophosphorus | Diazinon | 333-41-5
CAD071530380 | Organophosphorus | Disulfoton | 298-04-4
CAXCR9P200000004 | Carbamate | Carbaryl | 63-25-2
CAXCR9P200000004 | Carbamate | Carbofuran | 1563-66-2
CAXCR9P200000004 | Organophosphorus | Chlorpyrifos | 2921-88-2
CAXCR9P200000004 | Organophosphorus | Diazinon | 333-41-5
CAXCR9P200000004 | Organophosphorus | Disulfoton | 298-04-4
CAXCR9P200000004 | Organophosphorus | Malathion | 121-75-5
GAD033478389 | Carbamate | Carbofuran | 1563-66-2
GAD033478389 | Organophosphorus | Methamidophos | 10265-92-6
GAD033478389 | Organophosphorus | Methyl parathion | 298-00-0
GAD991275686 | Carbamate | Carbaryl | 63-25-2
GAD991275686 | Organophosphorus | Methyl parathion | 298-00-0
MAXCR1#MA0000047 | Carbamate | Carbaryl | 63-25-2
MAXCR1#MA0000047 | Organophosphorus | Chlorpyrifos | 2921-88-2
MD2210020036 | Carbamate | Carbaryl | 63-25-2
MD2210020036 | Carbamate | Propoxur | 114-26-1
MD2210020036 | Organophosphorus | Chlorpyrifos | 2921-88-2
MN8570024275 | Carbamate | Propoxur | 114-26-1
MN8570024275 | Organophosphorus | Diazinon | 333-41-5
MN8570024275 | Organophosphorus | Malathion | 121-75-5
MOD000830554 | Carbamate | Carbaryl | 63-25-2
MOD000830554 | Organophosphorus | Diazinon | 333-41-5
MOD000830554 | Organophosphorus | Disulfoton | 298-04-4
NCD980557656 | Carbamate | Carbaryl | 63-25-2
NCD980557656 | Carbamate | Carbofuran | 1563-66-2
NCD980557656 | Organophosphorus | Malathion | 121-75-5
NVXCRA7220000001 | Carbamate | Carbofuran | 1563-66-2
NVXCRA7220000001 | Organophosphorus | Chlorpyrifos | 2921-88-2
NVXCRA7220000001 | Organophosphorus | Diazinon | 333-41-5
NVXCRA7220000001 | Organophosphorus | Malathion | 121-75-5
TXD007349863 | Carbamate | Carbaryl | 63-25-2
TXD007349863 | Carbamate | Propoxur | 114-26-1
TXD007349863 | Organophosphorus | Chlorpyrifos | 2921-88-2
TXD007349863 | Organophosphorus | Diazinon | 333-41-5
TXD007349863 | Organophosphorus | Dichlorvos | 62-73-7
TXD007349863 | Organophosphorus | Dimethoate | 60-51-5
TXD007349863 | Organophosphorus | Malathion | 121-75-5
TXD007349863 | Organophosphorus | Methyl parathion | 298-00-0
TXN000605514 | Carbamate | Carbaryl | 63-25-2
TXN000605514 | Organophosphorus | Diazinon | 333-41-5
TXXCR6#TX0000006 | Carbamate | Carbaryl | 63-25-2
TXXCR6#TX0000006 | Organophosphorus | Acephate | 30560-19-1
TXXCR6#TX0000012 | Carbamate | Propoxur | 114-26-1
TXXCR6#TX0000012 | Organophosphorus | Acephate | 30560-19-1
WAD000643577 | Carbamate | Carbaryl | 63-25-2
WAD000643577 | Organophosphorus | Diazinon | 333-41-5
WAD000643577 | Organophosphorus | Ethion | 563-12-2
WAD000643577 | Organophosphorus | Malathion | 121-75-5
WAD000643577 | Organophosphorus | Methyl parathion | 298-00-0

a Information from the ATSDR HazDat and Sequoia database (through FY2007).

b Site IDs that are 12 characters long are for sites (usually defined by EPA). Site IDs that are 16 characters long are for events (like emergency events; always defined by ATSDR).

Table E-2 Sites with All Three Types of Pesticides^a^

Site event key^b^ | Type | Substance | CAS number
AZD980735666 | Carbamate | Carbaryl | 63-25-2
AZD980735666 | Carbamate | Methomyl | 16752-77-5
AZD980735666 | Organophosphorus | Diazinon | 333-41-5
AZD980735666 | Organophosphorus | Dimethoate | 60-51-5
AZD980735666 | Organophosphorus | Guthion | 86-50-0
AZD980735666 | Organophosphorus | Malathion | 121-75-5
AZD980735666 | Organophosphorus | Methyl parathion | 298-00-0
AZD980735666 | Pyrethroid | Permethrin | 52645-53-1
CO5210020769 | Carbamate | Methomyl | 16752-77-5
CO5210020769 | Organophosphorus | Chlorfenvinphos | 470-90-6
CO5210020769 | Organophosphorus | Dichlorvos | 62-73-7
CO5210020769 | Organophosphorus | Dicrotophos | 141-66-2
CO5210020769 | Organophosphorus | Malathion | 121-75-5
CO5210020769 | Organophosphorus | Methyl parathion | 298-00-0
CO5210020769 | Organophosphorus | Naled | 300-76-5
CO5210020769 | Organophosphorus | Stirofos | 22248-79-9
CO5210020769 | Pyrethroid | Fenvalerate | 51630-58-1
LAD981057706 | Carbamate | Aldicarb | 116-06-3
LAD981057706 | Carbamate | Carbofuran | 1563-66-2
LAD981057706 | Carbamate | Oxamyl | 23135-22-0
LAD981057706 | Organophosphorus | Chlorpyrifos | 2921-88-2
LAD981057706 | Organophosphorus | Diazinon | 333-41-5
LAD981057706 | Organophosphorus | Dimethoate | 60-51-5
LAD981057706 | Organophosphorus | Disulfoton | 298-04-4
LAD981057706 | Organophosphorus | Guthion | 86-50-0
LAD981057706 | Organophosphorus | Malathion | 121-75-5
LAD981057706 | Organophosphorus | Methyl parathion | 298-00-0
LAD981057706 | Organophosphorus | Naled | 300-76-5
LAD981057706 | Pyrethroid | Permethrin | 52645-53-1
NVXCRA7220000002 | Carbamate | Carbaryl | 63-25-2
NVXCRA7220000002 | Carbamate | Propoxur | 114-26-1
NVXCRA7220000002 | Organophosphorus | Chlorpyrifos | 2921-88-2
NVXCRA7220000002 | Organophosphorus | Diazinon | 333-41-5
NVXCRA7220000002 | Organophosphorus | Malathion | 121-75-5
NVXCRA7220000002 | Organophosphorus | Methyl parathion | 298-00-0
NVXCRA7220000002 | Pyrethroid | Cyfluthrin | 68359-37-5
NVXCRA7220000002 | Pyrethroid | Cypermethrin | 52315-07-8
NVXCRA7220000002 | Pyrethroid | Permethrin | 52645-53-1
NVXCRA7220000004 | Carbamate | Carbaryl | 63-25-2
NVXCRA7220000004 | Carbamate | Propoxur | 114-26-1
NVXCRA7220000004 | Organophosphorus | Chlorpyrifos | 2921-88-2
NVXCRA7220000004 | Organophosphorus | Diazinon | 333-41-5
NVXCRA7220000004 | Organophosphorus | Malathion | 121-75-5
NVXCRA7220000004 | Organophosphorus | Methyl parathion | 298-00-0
NVXCRA7220000004 | Pyrethroid | Cyfluthrin | 68359-37-5
NVXCRA7220000004 | Pyrethroid | Cypermethrin | 52315-07-8
NVXCRA7220000004 | Pyrethroid | Permethrin | 52645-53-1

a Information from the ATSDR HazDat database (through FY2007).

b Site IDs that are 12 characters long are for sites (usually defined by EPA). Site IDs that are 16 characters long are for events (like emergency events; always defined by ATSDR).