# Appendix D Chemical Structures of Mixture Components

Pyrethroid Insecticides

Allethrin

Chemical structure

Cyfluthrin (Baythroid)

Chemical structure

Bifenthrin

Chemical structure

Cyhalothrin

Chemical structure

Cypermethrin

Chemical structure

Cyphenothrin

Chemical structure

Deltamethrin

Chemical structure

Esfenvalerate

Chemical structure

Fenpropathrin (Danitol)

Chemical structure

Fenvalerate (Pydrin)

Chemical structure

Fluvalinate

Chemical structure

Imiprothrin

Chemical structure

Permethrin

Chemical structure

Resmethrin

Chemical structure

Tau-fluvalinate

Chemical structure

Tralomethrin

Chemical structure

Organophosphorus insecticides

Acephate

Chemical structure

Azinphos-methyl

Chemical structure

Bensulide

Chemical structure

Chlorethoxyfos

Chemical structure

Chlorpyrifos

Chemical structure

Diazinon

Chemical structure

Dichlorvos

Chemical structure

Dicrotophos

Chemical structure

Dimethoate

Chemical structure

Disulfoton

Chemical structure

Ethoprop

Chemical structure

Fenamiphos

Chemical structure

Fenthion

Chemical structure

Fosthiazate

Chemical structure

Malathion

Chemical structure

Methamidophos

Chemical structure

Methidathion

Chemical structure

Methyl-parathion

Chemical structure

Mevinphos

Chemical structure

Naled

Chemical structure

Omethoate

Chemical structure

Oxydemeton-methyl

Chemical structure

Phorate

Chemical structure

Phosalone

Chemical structure

Phosmet

Chemical structure

Phostebupirim

Chemical structure

Pirimiphos-methyl

Chemical structure

Profenofos

Chemical structure

Terbufos

Chemical structure

Tetrachlorvinphos

Chemical structure

Tribufos (merphos oxide)

Chemical structure

Trichlorfon

Chemical structure

Chlorfenvinphos

Chemical structure

Ethion

Chemical structure

Carbamate insecticides

Aldicarb

Chemical structure

Alidcarb sulfone

Chemical structure

Aldicarb sulfoxide

Chemical structure

Carbaryl

Chemical structure

Carbofuran

Chemical structure

Formetanate hydrochloride

Chemical structure

3-Hydroxycarbofuran

Chemical structure

5-Hydroxycarbofuran

Chemical structure

Methiocarb

Chemical structure

Methomyl

Chemical structure

Oxamyl

Chemical structure

Pirimicarb

Chemical structure

Propoxur (Baygon)

Chemical structure

Thiodicarb

Chemical structure