# Appendix C Background Information for Carbamates

Carbamate insecticides are structurally diverse derivatives of carbamic acid or N-methyl carbamic acid, which display a range of potencies in inducing toxic effects in mammals (Costa 2008). The carbamate insecticides discussed in this document (aldicarb, carbaryl, carbofuran, methomyl, oxamyl, and propoxur) are derivatives of N-methyl carbamic acid (EPA 2007b). Like organophosphorus insecticides, their principal and most well-studied effect in insects and mammals is neurological dysfunction mediated through inhibition of ChE (Baron 1991; Costa 2008). The differences in potencies of carbamate insecticides in producing toxic effects in mammals have been associated to a limited degree with structural differences influencing water solubility (Costa 2008). For example, aldicarb, with a water solubility of 6 g/L, is much more potent than carbaryl and carbofuran, with water solubilities of about 0.7 g/L; acute oral LD_50_ values for rats are 0.8, 10, and 400 mg/kg for aldicarb, carbaryl, and carbofuran, respectively (Costa 2008).

## C.1 Toxicokinetics

Carbamate insecticides are expected to be absorbed following inhalation, oral, and dermal exposures, and skin penetration is increased by organic solvents and emulsifiers present in commercial preparations (Costa 2008). Results from animal studies indicate that, after absorption, carbamates are rapidly distributed by the blood to tissues and organs, metabolized to water soluble products, and rapidly excreted, predominantly in urine with no bioaccumulation in tissues (Baron 1991). Carbamate insecticides inhibit ChE directly, and most metabolites of carbamate insecticides from pathways involving oxidation and hydrolysis do not inhibit ChE (Costa 2008). Aldicarb is an example of a carbamate, however, with metabolites (sulfoxide and sulfone derivatives) that are potent ChE inhibitors (Costa 2008).

## C.2 Health Effects

The principal and most well-studied effect of carbamate insecticides is neurological effects mediated by the inhibition of ChE (Costa 2008). EPA (2007b) determined that the N-methyl carbamate pesticides represent a common mechanism group based on similar structural characteristics and shared ability to inhibit ChE at the active enzymatic site.

The signs and symptoms of acute high-level exposure to carbamate insecticides are similar to those induced by organophosphorus insecticides: miosis, urination, lacrimation, diarrhea, muscle fasciculation, and central nervous system effects such as dizziness, mental confusion, depression of respiratory centers, and coma (Costa 2008). However, the carbamylated ChE is transiently inhibited, rapidly reversible, and does not undergo the irreversible aging reaction, which happens with organophosphorylated ChE (Costa 2008). Thus, cholinergic signs and symptoms of acute carbamate intoxication are generally resolved within a few hours (Costa 2008). Results from subchronic and chronic animal toxicity studies with carbamate insecticides have identified a number of effects including signs of ChE inhibition, kidney, liver or spleen effects, and decreased body weight gain, but ChE inhibition is a sensitive effect for all studied carbamate insecticides (EPA 2007b).

Results from developmental toxicity, developmental neurotoxicity, and reproductive toxicity studies with several carbamates (aldicarb, carbofuran, methoymyl, oxamyl, and baygon) provide no evidence for effects on reproductive performance from these chemicals and show that fetotoxic effects, such as decreased fetal body weight or delayed ossification of sternebrae, only occurred at doses equal to or greater than those inducing maternal toxicity (see Section C.4). EPA (2007b) compared NOAELs and LOAELs and BMDs from developmental neurotoxicity studies and ChE inhibition studies in animals and reported that, for three carbamates with appropriate data (aldicarb, carbaryl, and carbofuran), ChE inhibition was 10–100-fold more sensitive than developmental neurotoxic effects. As a result, in its cumulative risk assessment for N-methyl carbamates (see Section C.4), EPA (2007b) used ChE inhibition as the end point of concern, as well as the end point of concern for evaluating the FQPA 10X safety factor for infants and children.

## C.3 Mechanisms of Action

Neurotoxicity. The principal and common mode of action by which carbamates induce neurological effects in insects and mammals is inhibition of ChE (Baron 1991; Costa 2008). Carbamates rapidly bind to the active site of ChE, but the inhibition of enzyme function is transient and reversible because the reactivation of the carbamylated enzyme is rapid and no “aging” of the active site occurs, such as that which occurs with organophosphorus insecticides (Baron 1991; Costa 2008). EPA (2007b) determined that the N-methyl carbamate pesticides represent a common mechanism group based on similar structural characteristics and shared ability to inhibit ChE by carbamylation of the serine hydroxyl group located in the active site of the enzyme.

Even though some carbamates have been shown to inhibit NTE, they are not expected to cause delayed peripheral neuropathy such as that caused by organophosphorus insecticides, because the carbamylated enzyme does not age (Costa 2008).

Other Effects. Results from chronic exposure animal studies with a few carbamate insecticides have identified a few effects that occur at chronic administered dose levels similar to or slightly lower than those associated with ChE inhibition. The mechanism(s) by which these carbamate insecticides induce effects other than ChE inhibition is unknown.

## C.4 Health Guidelines

ATSDR has not prepared toxicological profile for any of the carbamate insecticides discussed in this document.

The EPA IRIS (IRIS 2013) lists chronic oral RfDs for aldicarb, carbaryl, carbofuran, methomyl, oxamyl, and baygon (also known as propoxur), and a more recent cumulative risk assessment for N-methyl carbamates is reported in EPA (2007b).

EPA (2007b) determined that N-methyl carbamate insecticides represent a common mechanism group based on similar structural characteristics and shared ability to inhibit ChE at the active enzymatic site. A multi-chemical, multi-pathway PBPK/PD model could not be developed for the cumulative risk assessment because appropriate pharmacokinetic data for model development were only available for one carbamate insecticide, carbaryl (EPA 2007b). Based on an analysis of available data, including data collected by EPA and data submitted for registration, EPA (2007b) concluded that acute ChE inhibition, measured at the peak time of effect, was the most sensitive effect from exposure to carbamates and thus, the pertinent effect of concern. A component-based RPF approach, assuming dose additivity, was used in the cumulative risk assessment. RPFs for 10 carbamates (and several carbamate metabolites—aldicarb sulfone, aldicarb sulfoxide, and 3- and 5-hydroxy carbofuran) were developed based on brain ChE inhibition data for adult rats (Table C-1). The rat brain ChE inhibition data were modeled with a dose-time response model to estimate BMD_10_ values (doses at which ChE was inhibited by 10%), and the RPF values were calculated by dividing the BMD_10_ value for the subject carbamate by the BMD_10_ value for the index carbamate, oxamyl (EPA 2007b). Oxamyl was chosen as the index chemical, because oxamyl, compared with the other nine carbamates, had the most robust database for all three pertinent routes of exposure (oral, dermal, inhalation).

Table C-1 EPA RPFs for Oral, Dermal, and Inhalation Exposure to Carbamate Insecticides Based on Rat Brain ChE Inhibition

Chemical | Oral RPF | Dermal RPF | Inhalation RPF
Aldicarb | 4 | ND | ND
Aldicarb sulfone^a^ | 3.44 | ND | ND
Aldicarb sulfoxide^a^ | 3.68 | ND | ND
Carbaryl | 0.15 | 0.71 | 0.51
Carbofuran | 2.4 | ND | ND
3- and 5-hydroxycarbofuran | 2.4 | ND | ND
Formetanate HCL | 2.18 | ND | ND
Methiocarb | 0.18 | 0.09 | 0.62
Methomyl | 0.67 | ND | ND
Oxamyl | 1 | 1 | 1
Primicarb | 0.02 | ND | ND
Propoxur | 0.11 | 0.03 | 0.18
Thiodicarb | 0.89 | ND | ND

a Values for aldicarb sulfone and aldicarb sulfoxide were calculated based on molecular weight conversions from aldicarb assuming equipotency to aldicarb. 3- and 5-Hydroxycarbofuran were assumed to be equipotent to carbofuran.

ChE = acetylcholinesterase; EPA = U.S. Environmental Protection Agency; ND = not derived due to lack of data; RPF = relative potency factor

Source: EPA 2007b

EPA (2007b) incorporated uncertainty and extrapolation factors into the cumulative risk assessment for carbamate insecticides in two ways:

1. Adjustment of the RPF: Chemical-specific information was evaluated, when available, to determine chemical-specific inter-species uncertainty factors (animal to human extrapolation) and FQPA factors to arrive at adjusted RPF values for children and adults (Table C-2). Chemical-specific FQPA factors were calculated, when appropriate data were available, by dividing the adult BMD_10_ by the pup BMD_10_ for ChE inhibition; in the absence of appropriate data, the default value of 10 was used. Chemical-specific interspecies uncertainty factors were calculated similarly when appropriate data were available to compare human BMD_10_ values for ChE inhibition with rat BMD_10_ values.
2. Incorporation into the Target MOE: A default uncertainty factor of 10 for intrahuman variability was taken as the target MOE for each of the carbamate insecticides. The PODs, used in the cumulative risk assessments to compare against exposure estimates, were the route-specific rat BMDL_10_ values for brain ChE inhibition shown in Table C-3.

Table C-2 EPA Adjusted Oral RPFs for Children and Adults Based on Inter-Species and FQPA Factors

Chemical | Oral RPF | Interspecies factor | FQPA factor for children | Adjusted RPF children | Adjusted RPF adult
Aldicarb | 4 | 2 | 2 | 16 | 8
Aldicarb sulfone | 3.44 | 2 | 2 | 13.8 | 6.9
Aldicarb sulfoxide | 3.68 | 2 | 2 | 14.7 | 7.4
Carbaryl | 0.15 | 10 | 1.8 | 2.7 | 1.5
Carbofuran | 2.4 | 10 | 2.75 | 66 | 24
3- and 5-hydroxycarbofuran | 2.4 | 10 | 2.75 | 66 | 24
Formetanate HCL | 2.18 | 10 | 2.03 | 44 | 22
Methiocarb | 0.18 | 10 | 10 | 18 | 1.8
Methomyl | 0.67 | 5 | 3.05 | 10 | 3.3
Oxamyl | 1 | 3 | 3.48 | 10 | 3
Primicarb | 0.02 | 10 | 10 | 2 | 0.2
Propoxur | 0.11 | 10 | 10 | 11 | 1.1
Thiodicarb | 0.89 | 10 | 10 | 89 | 8.9

EPA = U.S. Environmental Protection Agency; FQPA = U.S. Food Quality and Protection Act; RPF = relative potency factors

Source: EPA 2007b

Table C-3 Oral, Dermal, and Inhalation BMD_10_ and BMDL_10_ Values for Rat Brain ChE Inhibition by Oxamyl, the Index Chemical for the EPA Cumulative Risk Assessment for N-Methyl Carbamates

End point | Oral | Dermal | Inhalation
BMD_10_ | 0.24 mg/kg | 34.91 mg/kg | 0.0047 mg/L
BMDL_10_ | 0.18 mg/kg | 17.05 mg/kg | 0.0038 mg/L (converted to 0.66 mg/kg)

BMD = benchmark dose; BMDL = benchmark dose limit; ChE = acetylcholinesterase; EPA = U.S. Environmental Protection Agency

Source: EPA 2007b

EPA (2007b) conducted route-specific cumulative risk assessments for adult and child exposures to N-methyl carbamate insecticides by incorporating the RPF values into a MOE approach applied to food, water, and residential exposure pathways. The residential pathways comprised oral, dermal, and inhalation exposures. Concentrations of carbamate residues in appropriate media (e.g., food, drinking water) were multiplied by appropriate interspecies- and FQPA-adjusted RPF values (Table C-2) and summed to arrive at oxamyl-equivalent concentrations, which were then used in exposure models to estimate oxamyl equivalent intakes (in units of mg/kg) for the various exposure scenarios investigated. MOE values were calculated by dividing the appropriate oxamyl POD (e.g., the oral rat BMDL_10_—Table C-3—for oral exposure scenarios) by the estimated oxamyl equivalent intake. MOE values <10 were taken as values requiring some mitigation action; those >10 were assessed to be without the need for mitigation. EPA also determined total MOE values for combined estimates of food, water, and residential exposure scenarios, showing that the food pathway was the dominant exposure pathway for the general population.

EPA (IRIS 2013) classified aldicarb in Cancer Group D—not classifiable as to human carcinogenicity, based on no human carcinogenicity data and inadequate carcinogenicity data in animal studies. EPA (2007b) reviewed studies that found no statistically significant increases in tumor incidence in mice or rats in 2-year feeding studies or in mice in a skin painting study. EPA (IRIS 2013) noted that there were significant trends in pituitary tumors in female rats and fibrosarcomas in male mice in the feeding studies.

EPA (IRIS 2013) concluded that the assays were inadequate to assess the carcinogenicity of aldicarb, because maximum tolerated doses were not included in the assays. EPA (IRIS 2013) has not formally assessed the carcinogenicity of any other carbamate insecticide.

NTP (2011) has not assessed the possible carcinogenicity of carbamate insecticides.

IARC (2012) classified aldicarb and carbaryl in cancer Group 3—not classifiable as to carcinogenicity to humans, but has not assessed other carbamates for possible carcinogenicity.

## C.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The most clearly established end points of concern for carbamate insecticides are neurological effects mediated via the inhibition of ChE. ATSDR has not derived MRLs for any of the carbamate insecticides, but EPA (2007b) concluded that acute ChE inhibition, measured at the peak time of effect, was the most sensitive effect from exposure to carbamates and thus, the pertinent effect of concern in its cumulative risk assessment for N-methyl carbamates. Due to the lack of appropriate and readily available dose-response data for effects other than ChE inhibition for most carbamate insecticides, TTDs were not developed.

## C.6 References

Baron RL. 1991. Carbamate insecticides. In: Hayes WJ, Laws ER, eds. Handbook of pesticide toxicology. Vol 3: Classes of pesticides. San Diego, CA: Academic Press Inc., 1125–1189.
Costa LG. 2008. Toxic effects of pesticides. In: Klassen CD, ed. Casarett and Doull’s toxicology. The basic science of poisons. New York, NY: McGraw Hill Medical, 883–930.
EPA. 2007b. Revised N-methyl carbamate cumulative risk assessment. Washington, DC: U.S. Environmental Protection Agency. https://archive.epa.gov/pesticides/reregistration/web/pdf/nmc_revised_cra.pdf. March 29, 2013.
IARC. 2012. Agents reviewed by the IARC monographs. Volumes 1-106. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsAlphaOrder.pdf. March 28, 2013.
Institoris L, Papp A, Siroki O, . 2004. Comparative investigation of behavioral, neurotoxicological, and immunotoxicological indices in detection of subacute combined exposure with methyl parathion and propoxur in rats. Ecotoxicol Environ Saf 57(3):270–277. 10.1016/S0147-6513(03)00101-5.15041250
IRIS. 2013. Advanced search. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/search/index.cfm. March 28, 2013.
NTP. 2011. Report on carcinogens, Twelfth Edition. Research Triangle Park, NC: National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. March 28, 2013.