# Appendix B Background Information for Organophosphorus Insecticides

Organophosphorus compounds have been synthesized and developed as insecticides beginning in the 1940s and continuing to the present time (Costa 2008). Hundreds of organophosphorus compounds have been synthesized and commercialized as insecticides, and more than half of insecticides used are organophosphorus compounds (Costa 2008).

## B.1 Toxicokinetics

Most organophosphorus insecticides are expected to be absorbed following inhalation, oral, or dermal exposures, distributed by the blood to various tissues including nervous system tissues, rapidly metabolized, and eliminated as metabolites in the urine (the principal route of elimination) and feces without significant accumulation in tissues (ATSDR 1995, 1997a, 1997b, 1997c, 2000, 2001, 2003b, 2008a, 2008b). Many organophosphorus insecticides are metabolized, via CYP enzymes, to metabolites more potent than the parent compound in inhibiting ChE, the principal mode of action by which these compounds cause neurological effects: diazinon to diazoxon (ATSDR 2008a); guthion to gutoxon (ATSDR 2008b); ethion to monoxon (ATSDR 2000); methyl parathion to methyl paraoxon (ATSDR 2001); malathion to malaoxon (ATSDR 2003b); disulfoton to disulfoton sulfoxide, disulfoton sulfone, demeton S-sulfoxide, or demeton S-sulfone (ATSDR 1995); and chlorpyrifos to chlorpyrifos-oxon (ATSDR 1997b). For these organophosphorus insecticides, further metabolism of the potent ChE-inhibiting initial metabolites to other, often more polar, metabolites represent detoxification processes. Examples of detoxification processes include CYP-mediated dealkylation or dearylation of the parent compound, hydrolysis of oxon intermediates by A-esterases, and hydrolysis via reaction with B-esterases, such as carboxylesterases and butyrylcholinesterase (Costa 2008). Thus, the balance between the kinetics of bioactivation and detoxification is critical in the expression of the neurotoxicity of these chemicals. For direct-acting organophosphorus insecticides, metabolism represents a detoxification process. Examples of direct acting organophosphorus insecticides include chlorfenvinphos, which is metabolized by CYP monooxygenases, esterases, and glutathione S-transferases (ATSDR 1997a), and dichlorvos, which is metabolized by esterases and glutathione S-transferases (ATSDR 1997c). The extent of potential reactivation of organophosphate-inhibited acetylcholinesterase decreases with time, a phenomenon called aging. Aging is due to dealkylation of the alkoxyl group of the residue bound to the enzyme. The rate of ageing is proportional to the electron-donating capacity of the alkyl group (ATSDR 2008a, 2008b, 2003b).

## B.2 Health Effects

The critical and most well-studied effect of organophosphorus insecticides is the inhibition of ChE, which results in accumulation of acetylcholine at acetylcholine receptors and overstimulation of nerve junctions in the peripheral and central nervous systems (ATSDR 1995, 1997a, 1997b, 1997c, 2000, 2001, 2003b, 2008a, 2008b). Acute exposure to high doses of organophosphorus insecticides causes severe ChE inhibition associated with cholinergic signs and symptoms including lacrimation, perspiration, miosis, diarrhea, nausea, and vomiting, accompanied with cramps or muscle weakness, drowsiness, fatigue, mental confusion, convulsions, or coma. Numerous animal studies and limited controlled-exposure human studies have identified acute and repeated exposure levels (via oral, inhalation, dermal, or parenteral routes) resulting in inhibition of plasma, RBC, and/or brain ChE (ATSDR 1995, 1997a, 1997b, 1997c, 2000, 2001, 2003b, 2008a, 2008b). Inhibition of RBC or brain ChE in the 20–59% range is generally considered to be a “less serious” adverse neurological effect not associated with the gross signs and symptoms of serious neurological dysfunction resulting from high dose levels (ATSDR 1995, 1997a, 1997b, 1997c, 2000, 2001, 2003b, 2008a, 2008b).

The critical nature of ChE inhibition for acute, intermediate, and chronic exposure to organophosphate insecticides is reflected in the critical effects for ATSDR MRLs for organophosphorus insecticides, which are listed in Table B-1. Inhibition of either plasma, RBC, or brain ChE is the critical effect for the majority of ATSDR’s inhalation MRLs (9/10) and oral MRLs (21/25) for organophosphorus insecticides (Table B-1). The exceptions include:

- The intermediate inhalation MRL for malathion, which is based on nasal and larynx lesions in rats exposed for 13 weeks at an exposure level (100 mg/m^3^) that did not significantly inhibit RBC ChE (ATSDR 2003b; Table B-1). Decreased RBC ChE activity was observed at the next highest exposure level (450 mg/m^3^) in the principal study, and decreased RBC or brain ChE was the critical effect for the other MRLs for malathion (acute inhalation, intermediate oral, and chronic oral).
- The intermediate oral MRL for methyl parathion, which is based on nerve function deficits in rat dams given daily gavage doses on gestation days (GDs) 5–15 and extending through PNDs 1–28 (ATSDR 2001; Table B-1).
- The chronic oral MRL for methyl parathion, which is based on decreased hematocrit and RBC counts in rats exposed to methyl parathion in the diet for 2 years at a dose level (0.25 mg/kg/day) that did not significantly decrease RBC or brain ChE (ATSDR 2001; Table B-1). In the principal study, decreased RBC and brain ChE activities were reported in rats exposed to the next highest dose level of methyl parathion (2.5 mg/kg/day, Table B-1).

Table B-1 Critical Effects and PODs for ATSDR MRLs for Organophosphorus Insecticides

Critical | Chemical effect | POD | | Species and exposure | Other NOAELs (N) and LOAELs (L) for neurological or developmental effects (mg/kg/day or mg/m^3^ for N and L)
Critical | Chemical effect | NOAEL | LOAEL | Species and exposure | Other NOAELs (N) and LOAELs (L) for neurological or developmental effects (mg/kg/day or mg/m^3^ for N and L)
Acute inhalation exposure (mg/m^3^)
Dichlorvos, acute MRL | ↓ RBC ChE | 1.81; (0.2 ppm) | 4.34; (0.48 ppm) | Rats, continuous exposure, 3 days | Fetal body weight and number of live fetuses, mice or rabbits; N=0.44 (7 hours/day, GDs 6–15 or 6–10); L=ND
Disulfoton, acute MRL | ↓ RBC ChE | 0.5 | 1.8 | Rats, 4 hours/day, 5 days/week, 5 days
Guthion, acute MRL | ↓ RBC ChE | 1.24 | 4.72 | Rats, 6 hours/day, 5 days/week, 2 weeks
Malathion, acute MRL | ↓ RBC ChE | 65 | 123 | Rabbits, 6 hours | Nasal and eye irritation, volunteers, 2-hour exposure, N=21; L=85; no effect on plasma or RBC ChE
Intermediate inhalation exposure (mg/m^3^)
Dichlorvos, intermediate MRL | ↓ RBC ChE | 0.27; (0.03 ppm) | 1.26; (0.14 ppm) | Rats, 23 hours/day, GDs 1–20
Diazinon, intermediate MRL | ↓ RBC ChE | 1.57 | 11.6 | Rats, 6 hours/day, 5 days/week, 3 weeks
Disulfoton, intermediate MRL | ↓ RBC ChE and lethargy | 0.02 | 0.1 | Rats, 6 hours/day, 5 days/week, 3 weeks | ↓ RBC ChE, rats, 6 hours/day, 5 days/week, 13 weeks, N=0.16; L=1.4
Guthion, intermediate MRL | ↓ RBC ChE | 1.24 | 4.72 | Rats, 6 hours/day, 5 days/week, 12 weeks
Malathion, intermediate MRL | Nasal and larynx lesions | NI | 100 | Rats, 6 hours/day, 5 days/week, 13 weeks | ↓ RBC ChE, rats, 6 hours/day, 5 days/week, 13 weeks, N=100; L=450; ↓ RBC ChE, volunteers, 2 hours/day, 42 days, N=85; L=NI
Chronic inhalation exposure (mg/m^3^)
Dichlorvos, chronic MRL | ↓ RBC ChE | 0.05; (0.006 ppm) | 0.54; (0.06 ppm) | Rats, 23 hours/day, 2 years
Acute oral exposure (mg/kg/day)
Chlorfenvinphos, acute MRL | ↓ RBC ChE | NI | 2.4 | Rats, in diet for 10 days | ↓ brain ChE, rats, single gavage dose, N =1; L=2
Chlorpyrifos, acute MRL | ↓ plasma ChE | 0.03 | 0.10 | Humans, daily capsules for 9–20 days | ↓ RBC ChE, rat dams, gavage on GDs 6–15; N=0.1; L=1
Diazinon, acute MRL | ↓ RBC ChE | 0.6 | 1.2 | Rats, in diet for 12 days | Deficits in neurobehavioral tests, mouse offspring, gavage GDs 1–18, N=NI; L=0.18
Dichlorvos, acute MRL | ↓ brain ChE | NI | 4 | Rats, gavage, 1time/day for 14 days | Decreased fetal body weight and number of live fetuses, mice or rabbits; N=60 (mouse), 5 (rabbit); L=ND
Disulfoton, acute MRL | ↓ RBC ChE | 0.1 | 0.3 | Rat dams, gavage GDs 6–15 | Delayed ossification, rat fetuses, gavage GDs 6–15, N=0.3; L=1
Ethion, acute MRL | ↓ RBC and brain ChE | 0.06 | 0.71 | Dogs, in diet for 90 days | Delayed ossification, rat fetuses, gavage GDs 6–15, N=0.6, L=2.5; Fused sterna, rabbit fetuses, gavage GDs 6–18, N=2.4, L=9.6
Guthion, acute MRL | ↓ RBC and brain ChE | 1 | 2 | Rat dams, gavage GDs 6–15 | Misaligned sternebrae, mouse fetuses, gavage GDs 6–15, N=2.5, L=5
Intermediate oral exposure (mg/kg/day)
Chlorfenvinphos, intermediate MRL | ↓ immune responses | NI | 1.5 | Mice, gavage for 90 days | ↓ RBC ChE, rats, in diet for 12 weeks, N=3; L=10
Chlorpyrifos, intermediate MRL | ↓ plasma ChE | 0.03 | 0.1 | Humans, daily capsules for 9–20 days | ↓ RBC ChE, rat dams, gavage on GDs 6–15; N=0.1; L=1
Diazinon, intermediate MRL | ↓ RBC ChE | 0.18 | 0.27 | Rats, in diet for 42 days | ↓ RBC and brain ChE, dogs, in diet for 13 weeks; N=0.75, L=5.6; Deficits in neurobehavioral tests, mouse offspring, gavage GDs 1–18, N=NI, L=0.18
Dichlorvos, intermediate MRL | ↓ RBC ChE | 0.033 | NI | Humans, 3 times/day for 21 days
Disulfoton, intermediate MRL | ↓ brain ChE in F1a pups | 0.009 | 0.03 | Rats, in diet for 2 generations | ↓ RBC ChE, adult rats, in diet for 6 months, N=0.03, L=0.07
Ethion, intermediate MRL | ↓ RBC and brain ChE | 0.06 | 0.71 | Dogs, in diet for 90 days
Guthion, intermediate MRL | ↓ RBC ChE | 0.15 | 0.69 | Dogs, in diet for 26 weeks | ↓ RBC, rats, in diet 14 weeks pre-mating through postpartum day 5 or 28, F0 dams at postpartum day 5 or 28: N=NI; L=0.55; F1 pups at postpartum day 5 or 28: N=1.5, L=4.9; Gross neuromuscular incoordination and decreased fetal survival, rat offspring, gavage GD 6 through postpartum day 21, N=2.5, L=5
Malathion, intermediate MRL | ↓ RBC ChE | 0.24 | 0.34 | Humans, daily capsules for 32–56 days | ↓ brain ChE on PND 21, rat offspring, gavage on GDs 6–13; N=NI; L 138
Methyl parathion, intermediate MRL | Nerve function deficits | NI | 0.22 | Rats, gavage GDs 5–15 through PND 28 via dams, followed by gavage from weaning through 11–12 weeks of age | Nerve function deficits, rat offspring, gavage GDs 5–15 through PND 28 via dams only, N=0.88, L=NI; ↓ RBC and brain ChE, mouse, gavage 28 days, N=1; L=3; ↓ RBC and brain ChE, dogs, in diet 13 weeks, N=0.3; L=3
Chronic oral exposure (mg/kg/day)
Chlorfenvinphos, chronic MRL | ↓ RBC ChE | NI | 10 | Rats, in diet for 2 years | ↓ RBC ChE, dogs, in diet for 2 years, N=2; L=10
Chlorpyrifos, chronic MRL | ↓ RBC ChE | 0.1 | 1 | Rats, in diet for 2 years | ↓ RBC ChE, dogs, in diet for 1 year; N=0.1; L=1
Diazinon, chronic MRL | ↓ RBC ChE | 0.065 | 5.5 | Rats, in diet for 97 weeks | ↓ RBC and brain ChE, dogs, in diet for 52 weeks, N=0.017, L=4.6; Deficits in neurobehavioral tests, mouse offspring, gavage GDs 1–18, N=NI, L=0.18
Dichlorvos, chronic MRL | ↓ RBC and brain ChE | 0.05 | 1 | Dogs, 1 time/day, 52 weeks
Disulfoton, chronic MRL | ↓ RBC ChE | NI | 0.06 | Rats, in diet for 1.5–2 years | ↓ RBC and brain ChE, dogs, in diet for 2 years, N=0.03, L=0.14
Ethion, chronic MRL | ↓ RBC and brain ChE | 0.06 | 0.71 | Dogs, in diet for 90 days | ↓ RBC or brain ChE, rats or mice, in diet for 2 years, N=2 (rats) or 1.2 (mice), L=NI
Guthion, chronic MRL | ↓ RBC and brain ChE | 0.15 | 0.69 | Dogs, in diet for 52 weeks | ↓ RBC and brain ChE, rats, in diet 2 years, N=0.75, L=2.3
Malathion, chronic MRL | ↓ RBC ChE | 2 (males); 3 (females) | 29 (males); 35 (females) | Rats, in diet for 2 years
Methyl parathion, chronic MRL | Decreased hematocrit and RBC counts | 0.025 | 0.25 | Rats, in diet for 2 years | ↓ RBC and brain ChE, rats, in diet 2 years, N=0.25; L=2.5

ATSDR = Agency for Toxic Substances and Disease Registry; ChE = acetylcholinesterase; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NI = not identified; NOAEL = no-observed-adverse-effect level; PND = postnatal day; POD = point of departure; RBC = red blood cell

Sources: ATSDR 1995, 1997a, 1997b, 1997c, 2000, 2001, 2003b, 2008a, 2008b

- The intermediate oral MRL for chlorfenvinphos, which is based on decreased immune response in mice exposed to 1.5 mg/kg/day chlorfenvinphos for 90 days (ATSDR 1997a; Table B-1). Decreased RBC and brain ChE activities were observed in rats exposed to chlorfenvinphos in the diet for 12 weeks at 10 mg/kg/day, but not at 3 mg/kg/day (Table B-1). Decreased RBC ChE activity is the critical effect for the acute and chronic oral MRLs for chlorfenvinphos (Table B-1).

There is concern for the possible neurodevelopmental toxicity of organophosphorus insecticides, but most have not been evaluated for neurodevelopmental effects. As reviewed by EPA (2006), ChE has been suspected to play roles in the development of the neural system involving cell adhesion during neurite growth, but inhibition of the acetylcholine esterase activity by organophosphorus insecticides does not appear to be closely correlated with inhibition of neurite growth—some organophosphate insecticides inhibit neurite outgrowth in vitro, but others do not (EPA 2006). Many organophosphorus insecticides have been evaluated in standard developmental toxicity tests, but most have not been evaluated for neurodevelopmental effects. Concern for the neurodevelopmental effects of organophosphorus insecticides in general is raised by positive results found in a few studies that have been conducted. For example, offspring of mice exposed to 0.18 or 9 mg/kg/day diazinon on GDs 1–18 showed developmental delays and abnormal neuromuscular endurance and coordination (Spyker and Avery 1977). Similarly, offspring of rats exposed to 5 mg/kg/day guthion on GD 6 through PND 21 (weaning) showed gross neuromuscular incoordination and reduced survival; these effects were not observed in offspring of rats exposed to 2.5 mg/kg/day (Short et al. 1980). Another example is the finding that male rats showed electrophysiological changes in neural tissues following oral exposure to 0.22 mg/kg/day methyl parathion during GDs 5–15 (via the dam), lactational days 2–28 (via the dam), and PNDs 23–84, a dose below those inhibiting ChE in adult rats, but when exposure did not include PNDs 23–84, no effects were found, even at a dose level of 0.88 mg/kg/day (Desi et al. 1998).

There is also concern for the possible increased susceptibility of children, compared with adults, to the ChE inhibiting activity of organophosphorus insecticides, but the relative sensitivities of early life and adult stages of development have been assessed only for a few of these chemicals. In its cumulative risk assessment for organophosphorus insecticides, EPA (2006) applied a FQPA 10 safety factor to RPFs to provide protection for the possible susceptibility of infants to prenatal and postnatal toxicity, except for 13 insecticides with appropriate data evaluating ChE inhibition in juvenile and adult rats. These data were used to reduce the FQPA safety factor for 10 of these insecticides (see Section B.4 for more details). In concurrence with this recommendation, Costa (2008) concluded that there is evidence to indicate that young animals are more sensitive to acute toxicity from organophosphorus insecticides and the increased sensitivity appears to be due to lower detoxification abilities of young animals, compared with mature animals. Illustrating this conclusion, Slotkin (2006) cited published evidence that the LD_50_ value for chlorpyrifos in 1-day-old rats was about 10- and 100-fold less than LD_50_ values in 1-week-old and adult rats, respectively.

Exposure to certain organophosphorus insecticides has also been associated with two other neurological conditions that do not appear to involve ChE (Costa 2008). The “intermediate syndrome” has been described in 20–50% of acute organophosphorus poisoning cases with distinguishing features that develop one to several days after poisoning and can often resolve within 15 days (Costa 2008). Distinguishing features include weakness of respiratory, neck, and proximal limb muscles that can lead to mortality due to respiratory paralysis and associated complications. The mechanism of this syndrome is unknown, although it does not appear to involve ChE inhibition (Costa 2008).

“Organophosphate-induced delayed polyneuropathy” (OPIDP) is characterized by a progressive set of signs and symptoms associated with axonal degeneration starting with initial tingling of the hands and feet and progressing to sensory loss, muscle weakness of the lower and upper extremities, and ataxia (Costa 2008). Although initial phosphorylation of a nerve tissue esterase (neuropathy target esterase, NTE), followed by an aging reaction, are thought to be key events in the mode of action for OPIDP, events linking these effects on NTE to axonal degeneration have not been characterized. Organophosphorus agents that inhibit NTE, but do not age, do not cause OPIDP (Costa 2008). Commercial organophosphorus insecticides must undergo specific testing ensuring that cholinergic potency is much higher than potency in producing OPIDP, so this effect is not expected with general public or occupational exposures from the use of most organophosphorus insecticides. Nevertheless, symptoms characteristic of OPIDP have been described in several cases of high level poisoning from certain organophosphorus insecticides including chlorpyrifos, dichlorvos, isofenphos, methamidophos, mipafox, trichlorfon, and trichlornat (Lotti and Moretto 2005).

## B.3 Mechanisms of Action

Neurotoxicity. The principal and common mode of action by which organophosphorus insecticides cause neurological effects is through inhibition of ChE. The organophosphorus insecticides, and in some cases their metabolites, form stable phophorylated complexes with the active sites of ChE, preventing the enzymatic catalysis of the hydrolyzation of acetylcholine at nerve endings and nerve junctions and leading to excessive nerve stimulation and receptor desensitization (ATSDR 2008a, 2008b). Muscarinic effects from organophosphorus insecticides involve postganglionic parasympathetic nerve stimulation in end organs (e.g., heart, blood vessels, and secretory glands) and include miosis; excessive salivation, lacrimation, and rhinitis; vomiting; and diarrhea (ATSDR 2008a). Nicotinic effects from acetylcholine accumulation at skeletal muscle junctions and sympathetic preganglionic nerve endings include muscular fasciculations, weakness, tachycardia, and hypertension (ATSDR 2008a). Central nervous system effects from nerve stimulation in the cerebral cortex, hippocampus, and extrapyramidal motor system include respiratory depression, restlessness, mental confusion, drowsiness, ataxia, and coma (ATSDR 2008a).

For organophosphorus insecticides that are metabolized to more potent ChE inhibitors via CYP enzymes (e.g., diazinon is metabolized to diazoxon), coexposure to substances that induce or inhibit CYP enzymes may influence the toxic response to the parent insecticide as determined by the balance of the kinetics of activation and detoxification mechanisms (ATSDR 2008a). Inhibitors of enzymes involved in the metabolism of direct acting organophosphorus insecticides (e.g., dichlorvos and chlorfenvinphos) would be expected to enhance or prolong neurotoxic effects from these chemicals (ATSDR 1997a, 1997c).

Modes of action by which organophosphorus produce non-ChE-mediated neurological effects are poorly characterized. The “intermediate syndrome” of weakness of respiratory, neck, and proximal limb muscles has been hypothesized to result from nicotinic receptor desensitization due to chronic cholinergic stimulation, but molecular mechanisms are unknown (Costa 2008). OPIDP has been clearly associated with high-level exposure to certain organophosphorus agents that phosphorylate and “age” NTE, but events occurring between NTE aging and axonal degeneration are unknown (Costa 2008).

Organophosphorus insecticides have been shown to inhibit voltage-gated calcium channels (Meijer et al. 2014, 2015)

Neurodevelopmental Toxicity. Animal studies involving gestational exposure to some organophosphorus insecticides have noted mild delays in skeletal development at maternally toxic exposure levels, but most organophosphorus insecticides have not been evaluated for neurodevelopmental effects. In a recent review, Costa (2008) concluded that accumulating evidence from rodent studies in recent years indicates that perinatal exposure to organophosphorus insecticides can affect various cellular processes (e.g., neuronal survival, neurite outgrowth) and non-cholinergic pathways (e.g., serotoninergic synaptic functions), and cause various behavioral abnormalities. Slotkin (2006) recently reviewed evidence, predominantly from in vitro studies, that chlorpyrifos or its reactive metabolite, chlorpyrifos oxon, can influence neurodevelopment via multiple mechanisms, including: (1) alteration of acetylcholine concentrations leading to overstimulation of cholinergic receptors involved in signaling cascades important in neural development; (2) direct effects on expression and function with serotonin receptors involved in neural developmental signaling cascades; (3) direct effects on expression and function of signaling intermediates, such as adenylyl cyclase, and on expression of nuclear transcription factor; and (4) indirect effects, through generation of oxidative stress, on signaling pathways controlling cell replication, differentiation, growth, or apoptosis.

## B.4 Health Guidelines

ATSDR Guidelines Based on Neurotoxicity As discussed in the previous section, decreased RBC or brain ChE activity is the critical effect for the majority of ATSDR MRLs for organophosphorus insecticides. Table B-2 lists the MRLs, PODs, and uncertainty factors used in the derivations. For inhalation exposure scenarios, MRLs ranged from 0.006 to 0.2 mg/m^3^ for acute duration and from 0.0002 to 0.01 mg/m^3^ for intermediate duration (Table B-2). Only one chronic inhalation MRL was derived (0.0005 mg/m^3^ for dichlorvos). For oral exposure scenarios, MRLs ranged from 0.001 to 0.01 mg/kg/day for acute duration, from 0.00009 to 0.02 mg/kg/day for intermediate duration, and from 0.00006 to 0.02 mg/kg/day for chronic duration.

Table B-2 ATSDR MRLs for Organophosphorus Insecticides: PODs and Uncertainty Factors

Chemical | POD | | MRL | Uncertainty factor^a^
Chemical | NOAEL | LOAEL | MRL | Uncertainty factor^a^
Acute inhalation exposure (mg/m^3^)
Dichlorvos | 1.81; (0.2 ppm) | 4.34; (0.48 ppm) | 0.02 | 100 (10 AH, 10 HV)
Disulfoton | 0.5 | 1.8 | 0.006 | 30 (3 AH, 10 HV); applied to duration-adjusted NOAEL
Guthion | 1.24 | 4.72 | 0.02 | 30 (3 AH, 10 HV): applied to NOAEL(HEC), 0.5 mg/m^3^
Malathion | 65 | 123 | 0.2 | 100 (10 AH, 10 HV); applied to duration-adjusted NOAEL
Intermediate inhalation exposure (mg/m^3^)
Dichlorvos | 0.27; (0.03 ppm) | 1.26; (0.14 ppm) | 0.003 | 100 (10 AH, 10 HV)
Diazinon | 1.57 | 11.6 | 0.01 | 30 (3 AH, 10 HV); applied to duration-adjusted NOAEL
Disulfoton | 0.02 | 0.1 | 0.0002 | 30 (3 AH, 10 HV); applied to duration-adjusted NOAEL
Guthion | 1.24 | 4.72 | 0.01 | 30 (3 AH, 10 HV); applied to NOAEL(human equivalent concentration), 0.37 mg/m^3^
Malathion | NI | 100 | 0.02 | 1,000 (10 LN, 10 AH, 10 HV); applied to duration-adjusted LOAEL
Chronic inhalation exposure (mg/m^3^)
Dichlorvos | 0.05; (0.006 ppm) | 0.54; (0.06 ppm) | 0.0005 | 100 (10 AH, 10 HV)
Acute oral exposure (mg/kg/day)
Chlorfenvinphos | NI | 2.4 | 0.002 | 1,000 (10 LN, 10 AH, 10 HV)
Chlorpyrifos | 0.03 | 0.10 | 0.003 | 10 HV
Diazinon | 0.6 | 1.2 | 0.006 | 100 (10 AH, 10 HV)
Dichlorvos | NI | 4 | 0.004 | 100 (10 AH, 10 HV)
Disulfoton | 0.1 | 0.3 | 0.001 | 100 (10 AH, 10 HV)
Ethion | 0.06 | 0.71 | 0.002 | 30 (3 AH, 10 HV)
Guthion | 1 | 2 | 0.01 | 100 (10 AH,10 HV); applied to BMDL, 1 mg/kg/day
Intermediate oral exposure (mg/kg/day)
Chlorfenvinphos | NI | 1.5 | 0.002 | 1,000 (10 LN, 10 AH, 10 HV)
Chlorpyrifos | 0.03 | 0.1 | 0.003 | 10 HV
Diazinon | 0.18 | 0.27 | 0.002 | 100 (10 AH, 10 HV)
Dichlorvos | 0.033 | NI | 0.003 | 10 HV
Disulfoton | 0.009 | 0.03 | 0.00009 | 100 (10 AH, 10 HV)
Ethion | 0.06 | 0.71 | 0.002 | 30 (3 AH, 10 HV)
Guthion | 0.15 | 0.69 | 0.003 | 100 (10 AH, 10 HV); applied to BMDL, 0.29 mg/kg/day
Malathion | 0.24 | 0.34 | 0.02 | 10 HV
Methyl parathion | NI | 0.22 | 0.0007 | 300 (3 LN,10 AH, 10 HV)
Chronic oral exposure (mg/kg/day)
Chlorfenvinphos | NI | 10 | 0.0007 | 1,000 (10 LN, 10 AH, 10 HV)
Chlorpyrifos | 0.1 | 1 | 0.001 | 100 (10 AH, 10HV)
Diazinon | 0.065 | 5.5 | 0.0007 | 100 (10 AH,10 HV)
Dichlorvos | 0.05 | 1 | 0.0005 | 100 (10 AH, 10 HV)
Disulfoton | NI | 0.06 | 0.00006 | 1,000 (10 LN, 10 AH, 10 HV)
Ethion | 0.06 | 0.71 | 0.0004 | 150 (3 AH,10 HV, 5 for long-term effects and possible susceptibility of children)
Guthion | 0.15 | 0.69 | 0.003 | 100 (10 AH, 10 HV); applied to BMDL, 0.30 mg/kg/day
Malathion | 2 | 29 | 0.02 | 100 (10 AH, 10 HV)
Methyl parathion | 0.025 | 0.25 | 0.0003 | 100 (10 AH, 10 HV)

a Uncertainty factor abbreviations: AH for animal to human extrapolation; HV for human variability; LN for LOAEL to NOAEL extrapolation.

ATSDR = Agency for Toxic Substances and Disease Registry; BMDL = benchmark dose limit; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NI=not identified; NOAEL = no-observed-adverse-effect level; POD = point of departure

Sources: ATSDR 1995, 1997a, 1997b, 1997c, 2000, 2001, 2003b, 2008a, 2008b

EPA Guidelines Based on Neurotoxicity. Although EPA lists chronic oral RfDs for 17 organophosphorus insecticides on IRIS (IRIS 2013), these assessments are less up to date than the EPA OPP RPFs used in the cumulative risk assessment for organophosphorus insecticides (EPA 2006). Organophosphorus insecticides were determined to represent a common mechanism group based on similar structural characteristics and shared ability to inhibit ChE at the active site. Methamidophos was selected as the index chemical in a RPF approach that derived RPFs for 33 organophosphorus insecticides, based on adult rat brain ChE inhibition data, submitted to EPA under the pesticide registration program (EPA 2006). Based on an analysis of available data, EPA (2006) concluded that the time to peak ChE inhibition, the persistence of action following acute exposure, and the duration of exposure required to reach a steady-state level of ChE is influenced by a number of toxicokinetic and toxicodynamic factors and that RPFs should be based on rat studies of duration of ≥21 days (when steady-state levels of ChE inhibition are expected) in order to develop RPFs that are reproducible and applicable to human exposure scenarios of concern.

The RPF values (listed in Table B-3) were derived using BMD analyses of brain ChE activity data for adult female rats (female rats were generally more sensitive than male); the central tendency estimate of the dose of the index chemical resulting in 10% ChE inhibition (e.g., BMD_10_) was divided by BMD_10_ values for the other chemicals to derive the unadjusted RPFs. For estimating risks for children, the RPFs were adjusted by multiplication by the default FQPA 10 factor or replaced with chemical-specific FQPA factors, when appropriate data were available to compare juvenile and adult susceptibility to ChE inhibition (see Table B-3). Methamidophos was selected as the index chemical because it had the highest quality dose-response data and the most robust database for all three exposure routes of interest (oral, dermal, inhalation) among the evaluated organophosphorus insecticides. Route-specific BMD_10_ values for female rats exposed to the index chemical were selected as the POD for the cumulative risk assessments and are listed (along with BMDL_10_ values) in Table B-4.

EPA (2006) evaluated cumulative risks for various U.S. regions from organophosphorus pesticides in food, residential and recreational use, and drinking water. The residential pathways comprised oral, dermal, and inhalation exposures. In accordance with the 1996 FQPA, the RPF/MOE approach used RPF values, which were adjusted with chemical-specific or default uncertainty factors (FQPA factors) to protect infants and children. Concentrations of organophosphorus residues in appropriate media (e.g., food, drinking water) were multiplied by appropriate FQPA-adjusted RPF values (see Table B-3) and summed to arrive at methamidophos-equivalent concentrations, which were then used in exposure models to estimate methamidophos-equivalent intakes (in units of mg/kg/day) for the various exposure scenarios investigated. The exposure estimates for food were based on residue monitoring data collected by the U.S. Department of Agriculture’s Pesticide Data Program supplemented with information from the U.S. Food and Drug Administration’s Surveillance Monitoring Programs and Total Diet Study. Drinking water and residential exposures were estimated with probabilistic modeling approaches which were focused on U.S. regions where organophosphorus insecticide use was high and drinking water vulnerability was high. The exposure assessments indicated that exposure to organophosphorus insecticides from foods represents the dominant exposure pathway for the general population.

Table B-3 EPA RPFs for Oral, Dermal and Inhalation Exposures to Organophosphorus Insecticides, Based on Data for Brain ChE Inhibition in Female Rats and FQPA Factors used to Adjust the RPFs in Cumulative Risk Assessments

Chemical | Oral RPF | Dermal RPF | Inhalation RPF | FQPA factor^a^
Acephate | 0.08 | 0.0025 | 0.208 | 1
Azinphos-methyl | 0.1 | ND^b^ | ND | 4.5
Bensulide | 0.003 | 0.0015 | ND | 10
Chlorethoxyfos | 0.13 | ND | ND | 10
Chlorpyrifos | 0.06 | ND | ND | 1
Chlorpyrifos-methyl | 0.005 | ND | ND | 10
Diazinon | 0.01 | ND | ND | 10
DDVP (dichlorvos) | 0.03 | ND | 0.677 | 1
Dicrotophos | 1.91 | ND | ND | 1.7
Dimethoate | 0.32 | ND | ND | 1
Disulfoton | 1.26 | 0.47 | 6.596 | 2.2
Ethoprop | 0.06 | ND | ND | 10
Fenamiphos | 0.04 | 1.5 | 0.315 | 10
Fenthion | 0.33 | 0.015 | ND | 10
Fosthiazate | 0.07 | ND | ND | 2.6
Malathion | 0.0003 | 0.015 | 0.003 | 10
Methamidophos | 1 | 1 | 1 | 2
Methidathion | 0.32 | ND | ND | 10
Methyl-parathion | 0.12 | ND | ND | 10
Mevinphos | 0.76 | ND | ND | 10
Naled | 0.08 | 0.075 | 0.82 | 10
Omethoate | 0.93 | ND | ND | 10
Oxydemeton-methyl | 0.86 | ND | ND | 1
Phorate | 0.39 | ND | ND | 10
Phosalone | 0.01 | ND | ND | 10
Phosmet | 0.02 | ND | ND | 10
Phosteburpirim | 0.22 | ND | ND | 10
Pirimiphos-methyl | 0.04 | ND | ND | 10
Profenofos | 0.004 | ND | ND | 10
Terbufos | 0.85 | ND | ND | 6.5
Tetrachlorvinphos | 0.001 | 0.00075 | ND | 10
Tribufos | 0.02 | ND | ND | 10
Trichlorfon | 0.003 | 0.0075 | 0.087 | 10

a The default FQPA 10 factor was replaced with chemical-specific FQPA factors, when appropriate data were available to compare juvenile and adult susceptibility to ChE inhibition. In the EPA cumulative risk assessments, route-specific RPFs were adjusted by multiplying by the appropriate FQPA factor.

b ND = not determined due to lack of pertinent data.

ChE = acetylcholinesterase; EPA = U.S. Environmental Protection Agency; FQPA = U.S. Food Quality and Protection Act; RPF = relative potency factor

Source: EPA 2006

Table B-4 Oral, Dermal, and Inhalation BMD_10_ and BMDL_10_ Values for Adult Female Rat Brain ChE Inhibition by Methamidophos, the Index Chemical for the EPA Cumulative Risk Assessment for Organophosphorus Insecticides

End point | Oral (mg/kg/day) | Dermal (mg/kg/day) | Inhalation (mg/kg/day)
BMD_10_ | 0.08 | 2.12 | 0.39
BMDL_10_ | 0.07 | 1.77 | 0.21

BMD = benchmark dose; BMDL = benchmark dose limit; ChE = acetylcholinesterase EPA = U.S. Environmental Protection Agency

Source: EPA 2006

MOE values for the various age group and exposure scenario combinations were calculated by dividing the appropriate methamidophos POD (e.g., BMD_10_ = 0.08 mg/kg/day for oral exposure, see Table 5) by the appropriate methamidophos-equivalent intake estimate. The target MOE for the cumulative risk assessment was 100 to account for uncertainty in extrapolating from rats to humans (10) and uncertainty related to human variability in susceptibility to organophosphorus insecticides (10). EPA (2006) evaluated the available toxicity studies with human subjects and determined that none provided appropriate data to adjust the default inter-species or intra-species uncertainty factors. MOE values <100 were taken as values requiring some mitigation action; those >100 were assessed to be without the need for mitigation. The combined analysis of cumulative risk for three expected pathways (food + water + residential use) indicated combined MOEs at the 99.9^th^ percentile (of exposure) that were approximately >100 for all populations using 21-day average results. In this analysis, the food pathway dominated the combined MOEs. MOE values calculated for 95, 99^th^ and 99.9^th^ percentiles of 21-day average food intakes for children and adults are listed in Table B-5.

Table B-5 MOE Values for 95^th^, 99^th^, and 99.9% Percentiles of Cumulative 21-Day Average Intakes of Organophosphorus Insecticides in Food for U.S. Children and Adults

Age group | 95^th^ percentile | 99^th^ percentile | 99.9^th^ percentile
Children, 1–2 years old | 550 | 250 | 110
Children, 3–5 years old | 670 | 300 | 99
Adults, 20–49 years old | 820 | 610 | 280

MOE = margin of exposure

Source: EPA 2006

Cancer Guidelines. Most organophosphorus insecticides have not been evaluated for cancer. Among the 17 organophosphorus insecticides assessed on the EPA IRIS (IRIS 2013), only three have been assessed for carcinogenicity: acephate was classified in Cancer Group C—possible human carcinogen; dichlorvos was classified in Cancer Group B2—probable human carcinogen; and methidathion was classified in Cancer Group C—possible human carcinogen. Oral cancer slope factors were developed for acephate (0.0087 per mg/kg/day) and dichlorvos (0.29 per mg/kg/day). No oral slope factor was developed for methidathion.

NTP (2011) has not assessed any organophosphorus insecticides for carcinogenicity.

IARC (2012) has assessed the possible carcinogenicity of five organophosphorus insecticides. Dichlorvos was classified in Cancer Group 2B—possibly carcinogenic to humans. Parathion, malathion, methyl parathion, and tetrachlorvinphos were classified in Cancer Group 3—not classifiable as to its carcinogenicity to humans.

## B.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The most clearly established end points of concern for organophosphorus insecticides are neurological effects mediated via the inhibition of ChE. Inhibition of plasma, RBC, or brain ChE is the critical effect for the majority of ATSDR’s inhalation MRLs (9/10) and oral MRLs (23/25), regardless of duration of exposure. Based on results from in vivo animal tests for a few organophosphorus agents and in vitro mechanistic studies, there is concern for the possible neurodevelopmental toxicity of organophosphorus insecticides, but there are inadequate data to describe possible dose-response relationships for neurodevelopmental toxicity of most organophosphorus insecticides (Costa 2008; EPA 2006). Due to the lack of appropriate dose-response data for effects other than ChE inhibition for most organophosphorus insecticides, TTDs were not developed.

## B.6 References

ATSDR. 1995. Toxicological profile for disulfoton. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp65.pdf. March 29, 2013.
ATSDR. 1997a. Toxicological profile for chlorfenvinphos. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp83.pdf. March 29, 2013.
ATSDR. 1997b. Toxicological profile for chlorpyrifos. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp84.pdf. March 29, 2013.
ATSDR. 1997c. Toxicological profile for dichlorvos. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp88.pdf. March 29, 2013.
ATSDR. 2000. Toxicological profile for ethion. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp152.pdf. March 29, 2013.
ATSDR. 2001. Toxicological profile for methyl parathion. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp48.pdf. March 29, 2013.
ATSDR. 2003b. Toxicological profile for malathion. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp154.pdf. March 29, 2013.
ATSDR. 2008a. Toxicological profile for diazinon. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp86.pdf. March 29, 2013.
ATSDR. 2008b. Toxicological profile for guthion. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp188.pdf. March 29, 2013.
Costa LG. 2008. Toxic effects of pesticides. In: Klassen CD, ed. Casarett and Doull’s toxicology. The basic science of poisons. New York, NY: McGraw Hill Medical, 883–930.
Desi I, Nagymajtenyi L, Papp A, . 1998. Experimental model studies of pesticide exposure. Neurotoxicology 19(4–5):611–616.9745919
EPA. 2006. Organophosphorus cumulative risk assessment 2006 update. Washington, DC: U. S. Environmental Protection Agency.
IARC. 2012. Agents reviewed by the IARC monographs. Volumes 1–106. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsAlphaOrder.pdf. March 28, 2013.
Institoris L, Papp A, Siroki O, . 2004. Comparative investigation of behavioral, neurotoxicological, and immunotoxicological indices in detection of subacute combined exposure with methyl parathion and propoxur in rats. Ecotoxicol Environ Saf 57(3):270–277. 10.1016/S0147-6513(03)00101-5.15041250
IRIS. 2013. Advanced search. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/search/index.cfm. March 28, 2013.
Lotti M, Moretto A. 2005. Organophosphate-induced delayed polyneuropathy. Toxicol Rev 24:37–49. 10.2165/00139709-200524010-00003.16042503
NTP. 2011. Report on carcinogens, Twelfth Edition. Research Triangle Park, NC: National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. March 28, 2013.
Short RD, Minor JL, Lee CC, . 1980. Developmental toxicity of guthion in rats and mice. Arch Toxicol 43(3):177–186. 10.1007/BF00297583.7369866
Slotkin TA. 2006. Developmental neurotoxicity of organophosphates: A case study of chlorpyrifos. In: Gupta RC, ed. Toxicology of organophosphate and carbamate compounds. Boston, MA: Elsevier Academic Press, 293–314.
Spyker JM, Avery DL. 1977. Neurobehavioral effects of prenatal exposure to the organophosphate Diazinon in mice. J Toxicol Environ Health A 3(5–6):989–1002. 10.1080/15287397709529633.