# Appendix A Background Information for Pyrethroids

Pyrethroids are manufactured insecticides that are similar in chemical structure to pyrethrins, naturally occurring chemicals found in certain chrysanthemum flowers (ATSDR 2003a). The pyrethroids are more photostable than pyrethrins and are widely used in agriculture and in medical and veterinary products (EPA 2011a). In the 1990s, permethrin was the most frequently used pyrethroid in U.S. agricultural crop production, representing about 40% of the amount of pyrethroids applied to U.S. crops in this period (about 2.5 million pounds total pyrethroids per year; ATSDR 2003a). It has been estimated that pyrethroids account for about 25% of the recent global insecticide market (Costa 2008; Soderlund et al. 2002).

## A.1 Toxicokinetics

Based on studies in humans and animals, pyrethroids are expected to be absorbed via the oral, inhalation, and dermal routes of exposure (ATSDR 2003a). Following absorption, pyrethroids are rapidly and widely distributed to tissues, including central and peripheral nerve tissues (ATSDR 2003a). Biotransformation of pyrethroids involves the hydrolytic cleavage of the central ester bond catalyzed by carboxylesterases to yield carboxylic acid derivatives and phenoxybenzoic acid derivatives and oxidation of alcohol groups by CYP oxygenases (ATSDR 2003a; Costa 2008). For most pyrethroids, hydrolytic and oxidative metabolic transformations represent detoxification processes. Inhibitors of CYP and carboxylesterases enhance the toxicity of pyrethroids, and piperonyl butoxide (a CYP inhibitor) consequently is a component of many commercial pyrethroid formulations (Costa 2008). Results from animal studies indicate that pyrethroids are eliminated from the body within 4–12 days following oral exposure via urinary excretion of metabolites and fecal excretion of parent compounds and metabolites (ATSDR 2003a). A human PBPK model for simulating toxicokinetics of exposures to mixtures of deltamethrin, permethrin, cypermethrin, and cyfluthrin was used to reconstruct exposures from biomonitoring (Quindroit et al. 2019, 2021).

## A.2 Health Effects

Neurological effects are the principal effects associated with exposure to pyrethroids (ATSDR 2003a; EPA 2011a). Pyrethroid insecticides act by interfering with the function of voltage-gated sodium channels (VGSCs) in nerve cells, producing whole-body tremors associated with coma or seizures and death in mammals with acute exposure to high doses (ATSDR 2003a; EPA 2011a). Modification of the kinetics of VGSC activation and inactivation are thought to underlie acute clinical signs of pyrethroid neurotoxicity (EPA 2011a, 2011b). At nonlethal doses of pyrethroids, acute- and intermediate-duration studies with animals have reported signs of neurological impairment including increased excitability and aggressiveness, decreased grip strength and motor activity, and altered gait in rats given single doses of pyrethroids or repeatedly exposed to permethrin in the diet, and diarrhea in dogs given cyhalothrin in gelatin capsules daily for 26 weeks (ATSDR 2003a). Two types of pyrethroids are recognized based on syndromes of toxic signs observed in acutely exposed rats (ATSDR 2003a; EPA 2011a; Ray and Fry 2006; Soderlund et al. 2002). Both types have an acid and an alcohol structural moiety. Type II pyrethroids typically have a cyano substituent attached to the alpha carbon of the alcohol moiety, Type I pyrethroids do not (EPA 2011a). Type I pyrethroids (also known as “T” pyrethroids; e.g., bifenthrin, permethrin, resmethrin) produce marked behavioral arousal, aggressive sparring, increased startle response, and tremors progressing from fine to whole-body tremors and prostration (ATSDR 2003a; EPA 2011a; Ray and Fry 2006; Soderlund et al. 2002). Type II pyrethroids (also known as “CS” pyrethroids; e.g., cyfluthrin, cyhalothrin, cypermethrin, fenvalerate, fluvalinate, tralomethrin) produce salivation and coarse tremors progressing to choreoathetosis and clonic seizures. Some pyrethroids (cyphenothrin, flucythrinate, esfenvalerate, and fenpropathrin) produce a mixture of the signs assigned to the two syndromes (ATSDR 2003a; EPA 2011a; Ray and Fry 2006; Soderlund et al. 2002).

Standard developmental toxicity and reproductive toxicity tests in animals orally exposed to pyrethroids have found no consistent evidence for developmental toxicity or reproductive toxicity (ATSDR 2003a; EPA 2011a). EPA (2011a) reported the absence of prenatal sensitivity in 76 guideline studies submitted to EPA for 24 pyrethroids. ATSDR (2003a) evaluated developmental toxicity tests with permethrin and resmethrin and reproductive toxicity tests with cyhalothrin, cypermethrin, and resmethrin. Neurodevelopmental effects have not been consistently associated with oral exposure of rodents orally exposed to pyrethroids (bioallethrin or deltamethrin) during neonatal stages of development (ATSDR 2003a; Costa 2008). However, in its cumulative risk assessment for pyrethroids (see next paragraph), EPA (2011a, 2011c) used a 3X safety factor for childhood exposures from birth to <6 years of age based on: (1) rat PBPK model predictions of a 3-fold increase in pyrethroid concentrations in juvenile brains, compared with adult brains; (2) similar in vivo and in vitro pharmacodynamic responses to pyrethroids in juvenile and adult rats; and (3) evidence that rat VGSCs are more sensitive to pyrethroids than homologous human isoforms.

The EPA (2011a) OPP conducted a cumulative risk assessment for 16 pyrethrin/pyrethroid insecticides. The assessment used:

1. 24-hour exposure estimates for the general human population to 13–15 pyrethroids by three exposure pathways (food, water, and residential use);
2. a relative potency approach using neurobehavioral data in rats exposed to multiple gavage dose levels of each of 16 pyrethroids (including deltamethrin, the index chemical) to estimate doses expected to be without risk for acute neurobehavioral effects in humans;
3. a margin-of-exposure (MOE) analysis using a target MOE of 100 for adults (10 each for inter- and intra-species variability) and 300 for children (3 for a FQPA safety factor and 10 each for inter- and intra-species variability) and a POD for deltamethrin of 11 mg/kg/day.

The POD was the BMDL_20_ for incidence of rats with a composite score for acute clinical signs of neurological impairment based on measures of body temperature, tremors, clonic convulsions, salivation, and mobility. The EPA (2011a, 2011c) determined that the 10X FQPA safety factor would be reduced to 1X for all populations >6 years of age, including women of child-bearing age, based on the absence of pre-natal sensitivity in 76 guideline studies submitted to EPA for 24 pyrethroids. EPA retained a 3X safety factor for exposures from birth to <6 years of age, based on the reasons described in the previous paragraph.

Relative potencies derived by EPA (2011a) for pyrethroids are listed in Table A-1. Deltamethrin was selected as the index chemical, because it had one of the most robust databases of guideline and literature toxicity studies among the evaluated pyrethroids, and it was tested with three dose levels in the principal studies (EPA 2011a; Weiner et al. 2009), compared with two dose levels for the other candidate index chemical, permethrin (EPA 2011a). For food and water dietary exposure to deltamethrin equivalents, the MOE for the general population was 4,700, indicating no risk of concern. Analyses for age-related subgroups indicated that the MOE of highest concern, 2,000, was for infants <1 year old, but this value is also indicative of no risk of concern. For residential use of pyrethroid insecticides involving dermal and inhalation exposure, MOEs ranged for 3,000 to 240,000 for dermal exposures and from 130,000 to 10,000,000 for inhalation exposures.

The EPA IRIS files (IRIS 2013) present abbreviated summaries of results from unpublished animal toxicity tests and derived oral RfDs for 10 pyrethroids, but these files do not reflect the updated toxicity assessment conducted by the U.S. EPA OPP (EPA 2011a).

Table A-1 Relative Potency Estimates for Pyrethroids Included in the EPA (2011a) Screening-Level Cumulative Risk Assessment

Pyrethroid | Oral BMD_20_ | Oral RPF^b,c^
Allethrin | 135 | 0.11
Bifenthrin | 14.3 | 1.01
Cyfluthrin | 12.6 | 1.15
Lambda-cyhalothrin | 8.9 | 1.63
Cyphenothrin | 100^a^ | 0.15
Cypermethrin | 76.3 | 0.19
Deltamethrin ^d^ | 14.5 | 1.0
Esfenvalerate | 40.5 | 0.36
Fenpropathrin | 29 | 0.50
Tau-fluvalinate | 14.5 | 1.0
Imiprothrin | 750^a^ | 0.02
Permethrin | 156 | 0.09
Prallethrin | 150^a^ | 0.1
Pyrethrins | 800^a^ | 0.02
Resmethrin | 291 | 0.05

a Values estimated from studies other than the principal study. All other BMD_20_ values were estimated using benchmark dose (BMD) analyses of incidence data from the principal study of gavage-exposed rats. The incidences were for composite scores >4 on a 4–12 composite score based on measures of body temperature, tremors, clonic convulsions, salivation, and mobility.

b RPF = BMD_20_ of index chemical (deltamethrin) / BMD_20_ of subject chemical. For example, allethrin RPF = 14.5/135 = 0.11.

c RPFs for dermal and inhalation exposures were based on oral BMDs. Five percent absorption values were applied to dermal assessments, and no adjustments were made when assessing inhalation exposures.

d Chosen as the index chemical because it had the best dose-response data among candidate pyrethroids with robust databases. The point of departure (POD) in the cumulative risk assessment was the BMDL_20_ value of 11 mg/kg/day for deltamethrin.

## A.3 Mechanisms of Action

Neurotoxicity. Although mammals have been estimated to be about 3 orders of magnitude less sensitive to pyrethroids than insects (due to faster metabolism, higher body temperatures, and lower sensitivity of mammal, compared with insect, ion channel sites), the mode of action for pyrethroid neurotoxicity is expected to be the same in insects and mammals (O’Reilly et al. 2014; Ray and Fry 2006). Pyrethroids reversibly slow the closing of sodium channel gates in nerve cells and microglia during the depolarizing phase of an action potential (ATSDR 2003a; Costa 2008; Hossain et al. 2017). This ability of pyrethroids has been proposed to involve pyrethroid stimulation of protein phosphorylation (Ray and Fry 2006).

Other molecular target sites have been identified that may play roles in pyrethroid neurotoxicity including voltage-gated chloride channels, voltage-gated calcium channels; GABA-gated chloride channels, noradrenaline release, and voltage-gated calcium channels (Meijer et al. 2014, 2015; Ray and Fry 2006; Soderlund et al. 2002), but sodium channels appear to be the major target (Ray and Fry 2006). The neuropotency of pyrethroids is influenced by the presence or absence of a cyano group in the alpha position of the central ester bond (Type II pyrethroids contain a cyano group) and stereochemical orientation (e.g., the 1R conformation is more potent than the 1S conformation in Type I pyrethroids) (ATSDR 2003a; Costa 2008; EPA 2011a, 2011b). Type I (“T”) and II (“CS”) pyrethroids have different effects on the kinetics of the sodium channel opening and closing; these differences have been proposed to be the basis of the differences observed in the “T” and “CS” syndromes of toxic signs (Ray and Fry 2006). Type II pyrethroids cause a prolonged open state of the sodium channel, compared with Type I pyrethroids (EPA 2011a, 2011b).

The identification of multiple molecular target sites for various pyrethroids and different effects on VGSCs by Type I and II pyrethroids has led to uncertainty about whether pyrethroids represent a common mechanism group of chemicals (Ray and Fry 2006; Soderlund et al. 2002). However, all tested pyrethroids have been shown to affect the function of VGSCs (EPA 2011a, 2011b), and results from studies of motor activity in rats (Wolansky et al. 2009) and sodium influx in cultured cerebrocortical neurons (Cao et al. 2011) showed that actions of a mixture of 11 pyrethroids (that included both Type I and II pyrethroids) were consistent with a statistical model of dose additivity. Demonstration of dose additivity is consistent with a common mechanism of action. Based on these and other findings, EPA (2011a, 2011b) concluded that all pyrethroids represent a common mechanism group of structurally related chemicals that modify the kinetics of VGSCs leading to altered neuronal excitability and two syndromes of clinical signs of neurotoxicity.

For most pyrethroids, metabolic transformations represent detoxification processes; inhibition of CYP- and carboxylesterase-mediated metabolism is expected to enhance the toxicity of pyrethroids (Costa 2008). Evidence for a few pyrethroids indicates that neurotoxic action in mammals may involve metabolites, but this evidence appears to be presently equivocal and in need of further confirmation (Ray and Fry 2006). Neonatal rats have been reported to be 4–17 times more sensitive than adult rats to the acute neurotoxicity of permethrin or cypermethrin (Ray and Fry 2006). Potential explanations for this age-related susceptibility include lesser metabolic capacities in neonates and the existence of a specific type of sodium channel in neonatal rats showing a higher binding affinity for saxitoxin (Ray and Fry 2006). EPA (2011a, 2011c) concluded that the increased sensitivity of neonates to pyrethroids was attributable to increased pyrethroid concentrations in juvenile brains, compared with adult brains.

Neurodevelopmental Toxicity. Possible associations between oral exposure to pyrethroids and neurodevelopmental effects are not clearly established. One group of investigators reported that oral exposure of mice to bioallethrin or deltamethrin during early postnatal exposure (postnatal days [PNDs] 6–10) caused increases in spontaneous activity behavior at 4 months of age with doses in the range of 0.21–0.7 mg/kg, and decreased spontaneous activity at 4 months of age with a neonatal exposure to a higher dose level of 42 mg/kg; however, other investigators could not duplicate the findings of the first group of investigators (ATSDR 2003a). Shafer et al. (2005) concluded that current evidence is inadequate to establish neurodevelopmental toxicity as a possible human hazard associated with exposure to pyrethroids (Shafer et al. 2005). Similarly, Ray and Fry (2006) concluded that observations of developmental neurotoxic effects in animals repeatedly exposed to pyrethroids during neonatal periods need confirmation. However, EPA (2011a, 2011c) concluded, in its cumulative risk assessment for pyrethroids, that there was sufficient evidence of increased juvenile sensitivity (due to pharmacokinetic differences leading to increased brain concentrations in juveniles compared with adults) to warrant using a safety factor of 3 for children <6 years old.

Other Effects. Mode-of-action information on other effects found in studies of individual pyrethroids (e.g., decreased body weight, diarrhea, and decreased pup survival; see ATSDR 2003a) was not located. Some of these effects (e.g., decreased body weight, diarrhea) may be related to the actions of pyrethroids on the sodium channels of nerve cells; the mode of action for decreased pup survival and liver hypertrophy is unknown.

## A.4 Health Guidelines

For oral exposure, ATSDR (2003a) derived acute-duration MRLs for permethrin, cypermethrin, and cyhalothrin and intermediate-duration MRLs for permethrin and cyhalothrin. No chronic-duration oral MRLs were derived for any pyrethroids, but, because no clinical signs of neurotoxicity were observed in a 2-year study of rats exposed to 1,000 ppm permethrin in the diet (at estimated doses of 40 mg/kg/day), ATSDR (2003a) expected that the intermediate-duration oral MRL for permethrin would be protective for a chronic duration of exposure.

ATSDR (2003a) derived an MRL of 0.1 mg/kg/day for acute-duration oral exposure to permethrin based on a no-observed-adverse-effect level (NOAEL) of 25 mg/kg and a lowest-observed-adverse-effect level (LOAEL) of 75 mg/kg for neurological impairment in rats given single doses of the chemical (increased excitability and aggressiveness, abnormal motor movement, and decreased grip strength and motor activity). This derivation used an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

ATSDR (2003a) derived an MRL of 0.02 mg/kg/day for acute-duration oral exposure to cypermethrin based on a LOAEL of 20 mg/kg for neurological impairment in rats given single doses of the chemical (altered gait and decreased motor activity). This derivation used an uncertainty factor of 1,000 (10 for the lack of a NOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

ATSDR (2003a) derived an MRL of 0.01 mg/kg/day for acute-duration oral exposure to cyhalothrin based on a NOAEL of 1 mg/kg/day and a LOAEL of 2.5 mg/kg/day for diarrhea in dogs given the chemical daily in gelatin capsules for 26 weeks. This derivation used an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

ATSDR (2003a) derived an MRL of 0.2 mg/kg/day for intermediate-duration oral exposure to permethrin based on a NOAEL of 15.5 mg/kg/day and a LOAEL of 91.5 mg/kg/day for neurological impairment (hindlimb splay) in rats given permethrin in the diet for 13 weeks. This derivation used an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

ATSDR (2003a) derived an MRL of 0.01 mg/kg/day for intermediate-duration oral exposure to cyhalothrin based on a NOAEL of 1 mg/kg/day and a LOAEL of 2.5 mg/kg/day for diarrhea in dogs given the chemical daily in gelatin capsules for 26 weeks. As with the acute-duration MRL for cyhalothrin, this derivation used an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

In a cumulative risk assessment for pyrethroid insecticides, the U.S. EPA OPP (EPA 2011a) selected deltamethrin as the index chemical in a relative potency approach that derived relative potency factors for 14 additional pyrethroids and a BMDL_20_ POD of 11 mg/kg/day for deltamethrin. The RPF values (listed in Table A-1) were derived using benchmark dose (BMD) analyses of incidence data from the principal studies of gavage exposed rats (EPA 2011d; Weiner et al. 2009). The incidences were for composite scores >4 on a 4–12 scale, based on measures of body temperature, tremors, clonic convulsions, salivation, and mobility. RfDs for 10 pyrethroids are still listed on EPA IRIS (IRIS 2013), and more recent pyrethroid assessments are reported in EPA (2011a). The 2011 EPA relative potency assessment has the advantage of being predominantly based on data collected from a single laboratory, obviating the uncertainty from interlaboratory variability associated with subjectivity in behavioral assessments and pharmacokinetic differences from different gavage vehicles and volumes.

The International Agency for Research on Cancer (IARC 2012) classified deltamethrin, fenvalerate, and permethrin in Cancer Group 3—Not classifiable as to its carcinogenicity to humans. IARC (2012) has not evaluated the carcinogenic potential of other pyrethroids. The National Toxicology Program (NTP 2011), the EPA OPP (EPA 2011a), and the EPA IRIS program (IRIS 2013) have not formally evaluated the evidence for the human carcinogenic potential of pyrethroid insecticides.

## A.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The most clearly established end points of concern for pyrethroids are neurological effects mediated via the slowing of sodium channels in nerve cells during action potentials (ATSDR 2003a; EPA 2011a, 2011b). In the absence of mode-of-action data to indicate otherwise, other effects (which are the critical effects for ATSDR MRLs or EPA RfDs listed on IRIS, such as diarrhea, decreased body weight gain, decreased pup survival, and increased liver weight) are assumed to occur via the same mode of action. Thus, TTD values for other effects were not derived for the pyrethroid pesticides of concern. Neurodevelopmental TTD values for pyrethroids were not developed due the equivocal nature of evidence for associations between pyrethroids and neurodevelopmental effects. Results from standard developmental toxicity and reproductive toxicity tests with animals orally exposed to the 10 pyrethroids listed on EPA’s IRIS do not identify reproductive effects (e.g., effects on fertility) or standard developmental effects (e.g., developmental delays, malformations) as health hazards of concern from exposure to most pyrethroids, with the possible exception of resmethrin. More recently, EPA’s OPP reported that no prenatal sensitivity was observed in 76 guideline studies submitted for 24 pyrethroids (EPA 2011a).

## A.6 References

ATSDR. 2003a. Toxicological profile for pyrethrins and pyrethroids. Agency for Toxic Substances & Disease Registry. http://www.atsdr.cdc.gov/ToxProfiles/tp155.pdf. March 29, 2013.
Cao Z, Shafer TJ, Crofton KM, . 2011. Additivity of pyrethroid actions on sodium influx in cerebrocortical neurons in primary culture. Environ Health Perspect 119(9):1239–1246. 10.1289/ehp.1003394.21665567
Costa LG. 2008. Toxic effects of pesticides. In: Klassen CD, ed. Casarett and Doull’s toxicology. The basic science of poisons. New York, NY: McGraw Hill Medical, 883–930.
EPA. 2011a. Memorandum: Pyrethroid cumulative risk assessment. U.S. Environmental Protection Agency. October 4, 2011.
EPA. 2011b. Memorandum: Draft science policy paper for the proposed common mechanism grouping for the pyrethrins and synthetic pyrethroids. U.S. Environmental Protection Agency. June 30, 2011.
EPA. 2011c. Memorandum: Re-evaluation of the FQPA safety factor for pyrethroid pesticides. U.S. Environmental Protection Agency. June 27, 2011.
EPA. 2011d. Data evaluation report: An oral (gavage) acute neurotoxicity comparison study in rats. U.S. Environmental Protection Agency. MRID48333801. https://downloads.regulations.gov/EPA-HQ-OPP-2011-0746-0005/content.pdf. November 30, 2022.
Hossain MM, Liu J, Richardson JR. 2017. Pyrethroid insecticides directly activate microglia through interaction with voltage-gated sodium channels. Toxicol Sci 155(1):112–123. 10.1093/toxsci/kfw187.27655349
IARC. 2012. Agents reviewed by the IARC monographs. Volumes 1–106. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsAlphaOrder.pdf. March 28, 2013.
Institoris L, Papp A, Siroki O, . 2004. Comparative investigation of behavioral, neurotoxicological, and immunotoxicological indices in detection of subacute combined exposure with methyl parathion and propoxur in rats. Ecotoxicol Environ Saf 57(3):270–277. 10.1016/S0147-6513(03)00101-5.15041250
Meijer M, Dingemans MM, van den Berg M, . 2014. Inhibition of voltage-gated calcium channels as common mode of action for (mixtures of) distinct classes of insecticides. Toxicol Sci 141(1):103–111. 10.1093/toxsci/kfu110.24913802
Meijer M, Brandsema JA, Nieuwenhuis D, . 2015. Inhibition of voltage-gated calcium channels after subchronic and repeated exposure of PC12 cells to different classes of insecticides. Toxicol Sci 147(2):607–617. 10.1093/toxsci/kfv154.26187449
NTP. 2011. Report on carcinogens, Twelfth Edition. Research Triangle Park, NC: National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. March 28, 2013.
O’Reilly AO, Williamson MS, González-Cabrera J, . 2014. Predictive 3D modelling of the interactions of pyrethroids with the voltage-gated sodium channels of ticks and mites. Pest Manag Sci 70(3):369–377. 10.1002/ps.3561.23589444
Padilla S, Marshall RS, Hunter DL, . 2007. Time course of cholinesterase inhibition in adult rats treated acutely with carbaryl, carbofuran, formetanate, methomyl, methiocarb, oxamyl or propoxur. Toxicol Appl Pharmacol 210:202–209. 10.1016/j.taap.2006.11.010.
Quindroit P, Beaudouin R, Brochot C. 2019. Estimating the cumulative human exposures to pyrethroids by combined multi-route PBPK models: Application to the French population. Toxicol Lett 312:125–138. 10.1016/j.toxlet.2019.05.007.31077771
Quindroit P, Crépet A, Brochot C. 2021. Estimating human exposure to pyrethroids’ mixtures from biomonitoring data using physiologically based pharmacokinetic modeling. Environ Res 192:110281. 10.1016/j.envres.2020.110281.33031810
Seume FW, O’Brien RD. 1960. Metabolism of malathion by rat tissue preparations and its modification by EPN. Agric Food Chem 8:36–41.
Shafer TJ, Meyer DA, Crofton KM. 2005. Developmental neurotoxicity of pyrethroid insecticides: Critical review and future research needs. Environ Health Perspect 113(2):123–136. 10.1289/ehp.7254.15687048
Starr JM, Scollon EJ, Hughes MF, . 2012. Environmentally relevant mixtures in cumulative assessments: an acute study of toxicokinetics and effects on motor activity in rats exposed to a mixture of pyrethroids. Toxicol Sci 130(2):309–318. 10.1093/toxsci/kfs245.22872056
Weiner ML, Nemec M, Sheets L, . 2009. Comparative functional observational battery study of twelve commercial pyrethroid insecticides in male rats following acute oral exposure. Neurotoxicology 30(Suppl 1):S1–S16. 10.1016/j.neuro.2009.08.014.19748519
Wolansky MJ, Gennings C, DeVito MJ, . 2009. Evidence for dose-additive effects of pyrethroids on motor activity in rats. Environ Health Perspect 117(10):1563–1570. 10.1289/ehp.0900667.20019907