# SUMMARY

Lead, manganese, zinc, and copper were chosen as the subject mixture for this interaction profile based on an analysis of the most frequently occurring binary mixtures in completed exposure pathways at hazardous waste sites. These metals are commonly found in soil. The primary route of exposure for this mixture is likely to be oral and the durations of concern are intermediate and particularly chronic. The term "metals" is used in this profile for brevity and convenience, and is intended to refer to lead, manganese, zinc, and copper in inorganic compounds or as ions. Because no pertinent health effects data or physiologically based pharmacokinetic (PBPK) models were located for the quaternary mixture, exposure-based assessment of health hazards for this mixture depends on an evaluation of the health effects data for the individual metals and on the joint toxic action and mechanistic data for various combinations of these metals. This profile discusses and evaluates the evidence for joint toxic action among lead, manganese, zinc, and copper, and recommends how to incorporate concerns regarding possible interactions or additivity into public health assessments of sites where people may be exposed to mixtures of these chemicals.

Although occupational and environmental exposure studies of the trinary mixture of lead, zinc, and copper are available, they are not adequate as the basis for conclusions regarding the toxicity of this mixture due to inconsistencies in results across studies by a single group of investigators and deficiencies in study design. In general, the effects in workers coexposed to lead, zinc, and copper were characteristic of lead toxicity. Whether the coexposure to zinc and copper provided partial protection against these effects cannot be determined from the data. In animals exposed environmentally to lead, zinc, and copper (and cadmium), high bone burdens of lead and low tissue levels of copper were seen, in comparison with unexposed animals. The decreased copper in the tissues may reflect zinc inhibition of copper absorption, but again, no clear conclusions can be drawn from this study.

Most of the data regarding joint toxic action of the components of this mixture are for binary combinations of these metals. Data for the lead-zinc mixture are extensive, and for the lead-manganese, lead-copper, and zinc-copper mixtures are adequate to support some conclusions regarding the mode of joint toxic action. Many of these studies are reasonably relevant because they employed intermediate oral exposure, and investigated endpoints relevant to the critical and sensitive effects of the mixture components. Data for the manganese-zinc and manganese-copper mixtures, however, are inadequate. Based on these data, and on mechanistic data for the individual components, the predicted directions of interaction for the binary mixtures were primarily less than additive or additive, with exception of the effects of manganese on the toxicity of lead, which were predicted to be greater than additive. Further discussion of the predicted interactions is presented later in this section.

Because no adequate studies or PBPK models for the whole mixture are available, a components-based approach to the exposure-based assessment of the potential hazard to the public is recommended in this profile, consistent with ATSDR (2001a) guidance. The effects of concern for the mixture include the critical effects of the individual components, and effects in common that may become significant due to additivity or interactions. The critical effects of two of the mixture components, lead and manganese, are neurological. The critical effects of zinc are hematological, which is also a sensitive effect of lead. The recommended approach is to estimate endpoint-specific hazard indexes for the neurotoxicity of lead and manganese and for the hematotoxicity of lead and zinc in order to screen for noncancer health hazards from potential additivity. The qualitative weight-of-evidence (WOE) is applied to assess the potential impact of interactions of the mixture components on the neurological and hematological hazard. The critical effect of copper is hepatic. The recommended approach is to use the hazard quotient for copper, with application of the qualitative WOE to assess the potential impact of the other metals on the hepatic toxicity of copper. If an endpoint-specific hazard index or if the hazard quotient for copper is greater than unity, and/or if the qualitative WOE indicates that joint toxic action may be greater than additive, further evaluation is needed (ATSDR 2001a), using biomedical judgment and community-specific health outcome data, and taking into account community health concerns (ATSDR 1992).

Estimation of endpoint-specific hazard indexes and application of the WOE are appropriate when hazard quotients for two or more of the mixture components equal or exceed 0.1 (ATSDR 2001a). If only one or if none of the mixture components has a hazard quotient that equals or exceeds 0.1, further assessment of the joint toxic action is not needed because additivity and/or interactions are unlikely to result in significant health hazard. Appropriate health guidance values for use in estimating hazard quotients and hazard indexes are summarized (Minimal Risk Levels [MRLs]) or derived (target-organ toxicity doses [TTDs]) in this profile.

The WOE method was used to prepare binary weight-of-evidence determinations (BINWOEs) for the binary mixtures (ATSDR 2001a, 2001b). The BINWOEs are predictions of the plausible direction of interactions, when they occur, and the degree of confidence in the prediction (indicated by a numerical score). The BINWOEs are used qualitatively to estimate the impact of interactions on the endpoint-specific hazard indexes for neurological and for hematological effects, and on the unique hazard quotient for hepatic effects of copper. The BINWOE scores, when summed to give a combined WOE score, provide an overall indication of direction of interaction and confidence.

Neurological: The predicted direction of joint toxic action for neurological effects, an endpoint common to two components, is greater than additive for the effect of manganese on lead, less than additive for the effects of zinc and copper on lead, additive (no effect) for the effect of lead on manganese, and indeterminate for the effects of zinc and copper on manganese. The WOE score indicates that the potential health hazard may be less than estimated by the endpoint-specific hazard index for neurological effects, particularly for waste sites with relatively high hazard quotients for lead, copper, and zinc, and a lower hazard quotient for manganese. The indeterminate ratings for two of the BINWOEs (zinc and copper on manganese) are a source of uncertainty in assessments where manganese accounts for a great portion of the apparent neurological hazard.

Hematological: The potential health hazard for hematological effects is likely to be lower than indicated by the endpoint-specific hazard index for mixtures where lead, zinc, and copper predominate, because three of the BINWOEs for combinations of these metals were less than additive with moderate to high confidence, and the remaining one was additive. The BINWOE for manganese on lead was greater than additive with low-moderate confidence, for lead on manganese was additive, and for manganese on zinc was indeterminate. The WOE score indicates that the potential health hazard may be less than estimated by the endpoint-specific hazard index for hematological effects. The indeterminate BINWOE for manganese on zinc is a source of uncertainty.

Hepatic: The predicted effects of the other mixture components on the hepatic toxicity of copper are less than additive for zinc with high-moderate confidence, additive for lead, and indeterminate for manganese. Thus, the available data indicate the potential health hazard for hepatic effects may be less than predicted by the hazard quotient for mixtures where zinc and copper predominate. There is uncertainty with regard to the potential effect of manganese due to the lack of pertinent information.