# PEER REVIEW

A peer review panel was assembled for this profile. The panel consisted of the following members:

- Gail Charnley, Ph.D.
  Private Consultant in Toxicology
  HealthRisk Strategies
  Washington, DC
- Rolf Hartung, Ph.D., D.A.B.T.
  Professor Emeritus of Environmental Toxicology
  University of Michigan
  Ann Arbor, MI
- R. Craig Schnell, Ph.D.
  Vice President for Academic Affairs and Professor of Toxicology
  North Dakota State University
  Fargo, ND

All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.