# Appendix D Background Information for Copper

Copper is a naturally occurring element that exists in the environment as the free metal, and in the (I) and (II) oxidation states. Because the biological availability and toxicity of copper are related to the copper(II) oxidation state, ATSDR (1990) has focused on that form of copper.

One limitation of dose or exposure data for both human and animal studies is that the contribution to body burden from the diet generally is not discussed or known. Copper is an essential element that occurs naturally in the human diet, and is included in all commercial animal chows. Precise levels of intake are often not known, even for animal diets. Therefore, reported doses in experimental studies discussed in the following sections are for the intentionally administered copper, consistent with ATSDR (1990).

## D.1 Toxicokinetics

Copper is readily absorbed from the stomach and small intestine. Gastrointestinal absorption in humans has been estimated at 60%; the site of maximal absorption appears to be the stomach and upper intestine in humans and rats, and the lower small intestine in hamsters. The predominant mechanism of absorption is mucosal uptake and binding of copper to metallothionein. The copper bound to metallothionein is slowly released to the blood or excreted when the mucosal cells are sloughed off. Copper induces the synthesis of metallothionein. Thus, metallothionein appears to play a homeostatic role in copper bioavailability. Following release to the blood, copper is loosely bound to albumin and amino acids, and transported to the liver, where it is incorporated into ceruloplasmin and released into the plasma. In addition, excess absorbed copper is stored in the liver or excreted through the bile. Concentrations of copper in heathy adults are highest in the hair and nails, followed by the liver and brain (ATSDR 1990). In the fetus, however, copper is accumulated in the liver to 6- to 10-fold higher concentrations than in adult liver, while circulating concentrations of copper in the fetus are low (EPA 1987). This accumulated hepatic copper is then incorporated into ceruloplasmin by the neonatal liver and released into the circulation (EPA 1987). The major pathway for excretion of absorbed copper is through the bile, followed by fecal excretion. Reabsoption of biliary copper is negligible. Additional contributions to fecal copper excretion is from unabsorbed copper and copper from desquamated mucosal cells (ATSDR 1990).

## D.2 Health Effects

Copper is an essential element that is incorporated into numerous enzymes involved in hemoglobin formation, carbohydrate metabolism, catecholamine synthesis, and cross-linking of collagen, elastin, and hair keratin (ATSDR 1990). Copper can exist in two oxidation states Cu(I) to Cu(II). Copper is present in many oxidases where its ability to change oxidation states is integral to catalytic activity (Bremner and Beattie 1995). One of these enzymes is ceruloplasmin, a ferroxidase that oxidize ferrous iron to the ferric form. Because only ferric iron is bound to transferrin and transported to the bone marrow, this transformation is critically important to provide iron for hemoglobin synthesis (Friberg et al. 1986). Other copper metalloenzymes include cytochrome c oxidase, Zn/Cu superoxide dismutase, dopamine β-hydroxylase, tyrosinase (tyrosine hydroxylase), and ascorbic acid oxidase (ATSDR 1990; Institute of Medicine 2001). Dopamine β-hydroxylase transforms dopamine to norepinephrine, tyrosinase metabolizes tyrosine to dopa (precursor of dopamine), and monoamine oxidase is important in the metabolic degradation of serotonin, epinephrine, norepinephrine, and dopamine (Hardman and Limbird 1996).

The NRC (1989) has established ESADDIs for copper. The ESADDIs are 1.5–2.5 mg/day for adolescents (>11 years) and 1.5–3.0 mg/day adults. For children, the ESADDIs are 0.4–0.6 mg/day for infants from birth to 6 months, 0.6–0.7 mg/day for infants from 6 months to 1 year, 0.7–1.0 for children from 1 to 3 years, 1.0–1.5 mg/day for children from 4 to 6 years, and 1.0–2.0 mg/day for children 7 to 10 years of age. An RDA of 0.9 mg/day is reported in a prepublication document (Institute of Medicine 2001); the final version has not been published as of December 2001.

The dietary requirements for copper in rats is 5 ppm for growth and maintenance and 8 ppm for pregnancy and lactation (NRC 1995), and for growing pigs ranges from 6 ppm in 3–5 kg pigs to 3 ppm in 80–120 kg pigs (NRC 1998).

Little information is available regarding the toxicity of ingested copper to humans. Case reports of adverse effects following ingestion of large amounts of copper(II) in contaminated water or as suicide attempts include acute gastrointestinal distress, acute hemolytic anemia in a young child, hepatic micronodular cirrhosis in two infant siblings, hepatic centrilobular necrosis in adults, renal tubular necrosis or clinical evidence of renal tubular damage in a child and in adults. Reliable information on doses was not available (ATSDR 1990). Wilson’s disease, an autosomal recessive disorder that affects normal copper homeostasis, gives some information regarding potential targets of copper toxicity in humans. The disease is characterized by excessive retention of copper in the liver, decreased concentration of plasma ceruloplasmin, impaired biliary copper excretion, and hypercupruria. Adverse health effects seen in Wilson’s disease patients are hepatic and renal lesions and hemolytic anemia, similar to the effects observed in human case reports summarized in the previous paragraph. In addition, neurological effects, including poor coordination, tremor, and psychological impairment have been observed in this disease. These neurological manifestations have not been seen in normal humans who ingested high doses of copper or in animals (ATSDR 1990).

In animals exposed to oral intakes of copper well above normal dietary requirements for intermediate durations, effects included gastrointestinal effects (forestomach hyperplasia) at 28 mg/kg/day in rats and 155 mg/kg/day in mice, decreased hemoglobin and hematocrit in rats at ≥40 mg/kg/day and pigs at 14.6 mg/kg/day, increased systolic blood pressure (one study) in rats at 10 mg/kg/day, hepatic damage in rats (increased serum glutamic-oxaloacetic transaminase (SGOT) at 7.9 mg/kg/day and necrosis at ≥40 mg/kg day) and pigs (increased SGOT levels at 36 mg/kg/day), renal tubular damage in rats (hyaline-like droplets at 14 mg/kg/day and necrosis at ≥100 mg/kg/day necrosis), and developmental effects in mice (increased fetal mortality at ≥104 mg/kg/day and developmental abnormalities at ≥155 mg/kg/day). In addition, there is a single report of potential testicular effects: an increase in testes weight in rats at 130 mg/kg/day. The toxicological significance of this effect is uncertain because no histopathological examinations were performed. The rats appeared to develop tolerance to the hepatic and renal effects, as evidenced by regeneration of tissue. Information regarding potential neurotoxicity was limited. No neurobehavioral effects or changes in dopamine and norepinephrine were seen in rats at 12.5 mg/kg/day. In another study, a 25% decrease in 3,4-dihydroxyphenylacetic acid (dopamine metabolite), but no change in dopamine was seen in rats at 175 mg/kg/day. Thus, no clear evidence of neurological effects is available for copper (ATSDR 1990). Additional information on neurotoxicity has been reviewed in Section 2.2.4 of this Interaction Profile and includes inconsistent changes in neurotransmitter levels in the brain of rats exposed orally (Flora et al. 1989a) versus intraperitoneally (Malhotra et al. 1982) to excess copper, and an increased odds ratio for development of Parkinson’s disease in workers exposed to copper for more than 20 years (Gorell et al. 1997, 1999). These findings are not adequate to establish that copper causes neurological effects.

Decreased body weight gain has been reported in several studies in rats ingesting ≥100 mg/kg/day, in pigs ingesting 14.6 mg/kg/day, and in mice consuming 4.2 mg/kg/day (ATSDR 1990). It is possible that copper interference with zinc may account for this observation.

Data on potential neurological effects are inadequate.

An assessment by the Institute of Medicine (2001) concluded that there is little evidence to indicate that chronic exposure to copper (above essential levels) results in systemic effects other than liver damage. Gastrointestinal effects were considered of more concern for exposure through drinking water or beverages than from food, and for acute exposure than for chronic, as there is evidence of development of tolerance.

## D.3 Mechanisms of Action

Copper is essential for heme synthesis, as described in Section D.2, and as part of Zn/Cu superoxide dismutase, protects against free radical damage. Copper at excessive levels, however, inhibits enzymes such as glucose-6-phosphatase and glutathione reductase, by binding to enzyme sulfhydryl groups, thus interfering with their protection of cells from free radical damage. Inhibition of glucose-6-phosphatase leads to hemolysis. Copper can damage the proximal renal tubule directly, or indirectly as a consequence of hypotension or hemolysis. Metallothionein, a cysteine-rich, low-molecular-weight protein that binds copper in the gastrointestinal mucosa and other body tissues, provides some protection against copper toxicity; its synthesis is induced by copper (Barceloux 1999). In addition, copper is exported form mammalian cells via a copper-translocating adenosine triphosphatase (ATPase) (Dameron and Harrison 1998). Acute oral poisoning causes irritation and erosion of the epithelial lining of the gastrointestinal tract (Barceloux 1999).

## D.4 Health Guidelines

ATSDR (1990) did not derive any inhalation MRLS for copper because of a lack of suitable data. Oral MRLs were not derived for copper because of the lack of human data, lack of NOAEL values in the animal studies, development of tolerance in rats, and because of the essentiality of copper. Nor did ATSDR (1990) suggest a suitable guidance value in this relatively early toxicological profile.

The NRC (1989) derived an estimated safe and adequate daily dietary intake for copper of 1.5–3 mg/day for adults. The NRC noted that copper balance studies in humans indicate that 1.6 mg/day is needed to replace fecal, urinary, and body surface losses of copper, but many U.S. diets provide less than 1.6 mg of copper per day, yet anemia or neutropenia ascribable to copper deficiency is not observed in adults consuming typical U.S. diets, suggesting either a homeostatic adaptation to low dietary copper, or an incorrect estimate of dietary copper intake. For these reasons, the NRC concluded that an RDA for copper cannot be established. More recently, an RDA has been estimated at 0.9 mg/day (≈0.013 mg/kg/day) (Institute of Medicine 2001: prepublication document, final version not published as of December 2001). The critical effect for overexposure to copper was considered to be liver damage, and an UL of 10 mg/day (≈0.14 mg/kg/day) of copper was established for adults (≥19 years old).

EPA (IRIS 2001) does not list an RfC or RfD for copper.

The National Toxicology Program (NTP 2001) does not list copper as a substance known or reasonably anticipated to be a human carcinogen and IARC has not published a monograph on the potential carcinogenicity of copper. EPA (IRIS 2001) has classified copper in Group D—not classifiable as to human carcinogenicity, based on a lack of human data, inadequate animal data, and equivocal mutagenicity data.

## D.5 Derivation of Target Organ Toxicity Dose (TTD) Values

A TTD for the hepatic effects of oral exposure to copper was derived to serve as a provisional value until such time as the toxicological profile on copper is updated. An RDA has been estimated at 0.9 mg/day (≈0.013 mg/kg/day) by the Institute of Medicine (2001: prepublication document, final version not published as of December 2001). In addition, an UL of 10 mg/day (≈0.14 mg/kg/day) of copper was established for adults (≥19 years old). The critical effect for overexposure to copper was considered to be liver damage. Pending publication of the final version of the documentation by the Institute of Medicine, this UL appears suitable for use as a TTD_HEPATIC_ for copper.

### Summary (TTD for Copper)

TTD_HEPATIC_ = 0.14 mg/kg/day

## D.6 References

ATSDR. 1990. Toxicological profile for copper. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Barceloux DG. 1999. Copper. Clin Toxicol 37(2):217–230.
Bremner I, Beattie JH. 1995. Copper and zinc metabolism in health and disease: Speciation and interactions. Proc Nutr Soc 54:489–499.8524895
Dameron CT, Harrison MD. 1998. Mechanisms for protection against copper toxicity. Am J Clin Nutr 67:1091S–1097S.9587158
EPA. 1987. Summary review of the health effects associated with copper. Health Issue Assessment. Cincinnati, OH: Environmental Criteria and Assessment Office. U.S. Environmental Protection Agency, 29.
Flora SJS, Coulombe RA, Sharma RP, 1989a. Influence of dietary protein deficiency on lead-copper interaction in rats. Ecotoxicol Environ Saf 18:75–82.2776691
Friberg L, Nordberg GF, Vouk VB, eds. 1986. Handbook on the toxicology of metals. 2^nd^ ed, Vol. II: Specific Metals. Amsterdam: Elsevier Science Publishing Co. Inc, 242, 668, 671.
Gorell JM, Johnson CC, Rybicki BA, 1997. Occupational exposure to metals as risk factors for Parkinson's disease. Neurology 48:650–658.9065542
Gorell JM, Johnson CC, Rybicki BA, 1999. Occupational exposure to manganese, copper, lead, iron, mercury and zinc and the risk of Parkinson’s disease. Neurotoxicology 20(2–3):239–248.10385887
Hardman JF, Lmbird LE, eds. 1996. Goodman & Gilman’s the pharmacological basis of therapeutics. New York, NY: McGraw-Hill, 120, 123–124, 252.
Institute of Medicine. 2001. Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc. Washington, DC: National Academy Press, 7–1 – 7–27. Http://www.nap.edu/books/0309072794/html/. December 19, 2001.
IRIS. 2001. Integrated Risk Information System. U.S. Environmental Protection Agency. Http://www.epa.gov/iris/subst/index.htm. April 17, 2001.
Malhotra KM, Shukla GS, Chandra SV. 1982. Neurochemical changes in rats co-exposed to lead and copper. Arch Toxicol 49:331–336.6284090
NRC. 1989. Recommended dietary allowances. 10^th^ ed. Washington, DC: National Academy Press. National Research Council, 205–213, 224–235, 284–285.
NRC. 1995. Nutrient requirements of laboratory animals. 4^th^ ed. Washington, DC: National Academy Press. National Research Council, 11–102.
NRC. 1998. Nutrient requirements of swine. 10^th^ ed. Washington, DC: National Academy Press. National Research Council, 47–49, 110–111, 115–116, 121–122.
NTP. 2001. 9^th^ report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services. National Toxicology Program. Http://ehis.niehs.nih.gov/roc/toc9.html. September 11, 2001.